# 24 Health Information Exchange among U.S. Non-federal Acute Care Hospitals: 2008–2014

Increasing the interoperable exchange of health information across the care continuum and individuals is a nationwide priority (1,2). The Office of the National Coordinator for Health IT (ONC) recently issued Connecting Health and Care for the Nation: A Shared Nationwide Interoperability Roadmap Version 1.0 (http://www.healthit.gov/sites/default/files/nationwide-interoperability-roadmap-draft-version-1.0.pdf), which specifies actions by public and private stakeholders to enable a majority of individuals and providers across the care continuum to send, receive, find, and use a common set of electronic clinical information by the end of 2017. Monitoring trends in electronic exchange of health information among hospitals is a critical component of assessing nationwide progress on exchange and interoperability across the care continuum. This brief updates analysis from 2013 (3), and describes trends in electronic health information exchange among non-federal acute care hospitals from 2008 to 2014.

## Three-quarters of hospitals electronically exchanged health information with outside providers in 2014.

Figure 1 Percent of non-federal acute care hospitals that electronically exchanged laboratory results, radiology reports, clinical care summaries, or medication lists with ambulatory care providers or hospitals outside their organization: 2008–2014.

NOTES: *Significantly different from previous year (p < 0.05).

Figure displays a single line chart. The line describes the percent of hospitals that exchange health information with any provider outside their organization from 2008 to 2014 (2008, 41%; 2009, 45%; 2010, 44%; 2011, 50%; 2012, 58%; 2013, 62%, 2014 76%).

SOURCE: ONC/American Hospital Association (AHA), AHA Annual Survey Information Technology Supplement.

★ Hospitals’ electronic health information exchange with hospitals or ambulatory care providers outside their organization increased by 85% from 2008 to 2014, and increased by 23% since last year (2013).

## Since 2010, most states experienced growth in electronic health information exchange among hospitals and outside providers.

Figure 2 Percent of non-federal acute care hospitals that electronically exchanged laboratory results, radiology reports, clinical care summaries, or medication lists with ambulatory care providers or hospitals outside their organization: 2010 and 2014.

This figure contains two maps of the United States comparing states growth in electronic health information exchange among hospital and outside providers in 2010 and 2014.

SOURCE: ONC/American Hospital Association (AHA), AHA Annual Survey Information Technology Supplement.

★ In 2014, 47 states and the District of Columbia had at least 60% or more of their hospitals electronically exchange key clinical data with outside providers. In contrast, in 2010, 10 states had 60% or more of their hospitals electronically exchange key clinical data with outside providers.
★ In 2014, state rates of hospitals’ electronic exchange of key clinical data with outside providers ranged from 42% to 100%; whereas in 2010, hospitals’ health information exchange with outside providers ranged from 24% to 67% (Appendix Table 1).

## Hospital to hospital electronic health information exchange increased by 55% between 2013 and 2014.

Figure 3 Percent of non-federal acute care hospitals that electronically exchanged laboratory results, radiology reports, clinical care summaries, or medication lists with outside providers and hospitals: 2008–2014.

NOTES: *Significantly different from previous year (p < 0.05).

Figure contains two line charts. The first describes the percent of hospitals that exchange health information with ambulatory providers outside their organization from 2008 to 2014 (2008, 36%; 2009, 40%; 2010, 38%; 2011, 44%; 2012, 51%; 2013, 57%; 2014, 69%). The second describes the percent of hospitals that exchange health information with other hospitals outside their organization from 2008 to 2014 (2008, 15%; 2009, 17%; 2010, 19%; 2011, 25%; 2012, 36%; 2013, 40%; 2014, 62%).

SOURCE: ONC/American Hospital Association (AHA), AHA Annual Survey Information Technology Supplement.

★ Close to seven in ten hospitals (69%) electronically exchanged health information with ambulatory providers outside of their system in 2014. This represents a 92% increase since 2008 and a 21% increase since last year.
★ In 2014, the exchange gap among hospitals and outside hospitals and ambulatory providers began to narrow as hospital to hospital exchange increased by 55%.
★ More than six in ten hospitals (62%) electronically exchanged health information with hospitals outside of their system in 2014. This represents a four-fold increase since 2008.

## In 2014, there were significant increases in electronic health information exchange across all data types among hospitals and outside providers.

Figure 4 Percent of non-federal acute care hospitals that electronically exchanged laboratory results, radiology reports, clinical care summaries, and medication history with any outside providers: 2008 to 2014.

NOTES: Appendix Table A2 contains annual point estimates for each of the four data types.

Figure is a line and point chart with lines that show the percent of hospitals that exchange lab results, radiology reports, clinical care summaries and medication history electronically with any outside providers from 2008 to 2014. The percent of hospital exchanging laboratory results in 2008 was 35% and in 2014 69%. The percent of hospital exchanging radiology reports in 2008 was 37% and in 2014 65%. The percent of hospital exchanging clinical care summaries in 2008 was 25% and in 2014 64%. The percent of hospital exchanging medication histories in 2008 was 21% and in 2014 64%.

SOURCE: ONC/American Hospital Association (AHA), AHA Annual Survey Information Technology Supplement.

★ Hospital exchange of laboratory results, radiology reports, clinical care summaries and medication history data with ambulatory care and hospitals outside their organization have all significantly increased between 2013 and 2014.
★ Approximately two-thirds of hospitals electronically exchanged laboratory results (69%), radiology reports (65%) and clinical care summaries (64%) with outside providers in 2014.
★ Close to six in ten (58%) hospitals exchanged medication history with outside providers. This is an increase of 176% since 2008 and an increase of 57% since last year.
★ Hospitals exchange of clinical care summaries with outside providers has more than doubled since 2008 and increased by 52% since last year.

## Clinical care summary exchange among hospitals and outside providers increased in 49 states and in the District of Columbia between 2010 and 2014.

Figure 5 Percent of non-federal acute care hospitals that electronically exchanged clinical care summaries with ambulatory care providers or hospitals outside their organization: 2010 and 2014.

This figure contains two maps of the United States comparing states by whether their hospitals exchange clinical care summaries with any providers outside their organization in 2010 and 2014. All estimates meet standards of reliability.

SOURCE: ONC/American Hospital Association (AHA), AHA Annual Survey Information Technology Supplement.

★ In 2014, 42 states had the majority of their hospitals electronically exchange clinical care summaries with outside providers. In contrast, in 2010, no states had the majority of their hospitals electronically exchange key clinical data with outside providers.
★ In 2014, state rates of hospitals’ electronic exchange of clinical care summaries with outside providers ranged from 30% to 88%; compared to a range of zero to 43% in 2010 (Appendix Table 3).

## Summary

Accelerating the availability of electronic health information to guide decision making and promoting care coordination are core strategies of HHS efforts to improve U.S. health care delivery (4). Hospitals not only deliver care to millions of Americans, but also have a critical role in coordinating care with a variety of providers across numerous settings. To advance the sharing of electronic health information, stage 2 of the Medicare and Medicaid Electronic Health Record (EHR) Incentive Programs requires hospitals to exchange clinical information during care transitions using certified health IT to receive incentive payments (5).

We found evidence to support that electronic exchange of health information is increasing among hospitals. More than three-quarters (76%) of non-federal acute care hospitals electronically exchanged laboratory results, radiology reports, clinical care summaries, and/or medication lists with any outside providers. This represents an 85% increase since 2008 and a 23% increase since last year. Close to seven in ten hospitals (69%) electronically exchanged health information with ambulatory providers outside of their organization, representing a 92% increase since 2008 and a 21% increase since last year.

In 2008, prior to the Health Information Technology for Economic and Clinical Health (HITECH) Act, only 15% percent of hospitals electronically exchanged health information with hospitals not part of their system. Prior research found that hospitals had significantly higher rates of exchange with outside ambulatory care providers compared to outside hospitals (6). In the past, competition among hospitals and cross-vendor interoperability were cited as barriers to exchange among outside hospitals (7,8); however, we found that this gap has narrowed. The percent of hospitals that electronically exchanged clinical data with outside hospitals (62%) has quadrupled since 2008; and grew by 55% between 2013 and 2014.

We also had previously reported that hospitals’ exchange with outside providers significantly varied by the type of data exchanged, with hospitals electronically exchanging laboratory results and radiology reports at much higher rates than clinical care summaries and medication history (3,6). In 2014, the gap in variation by data type started to close. More than six in ten hospitals exchanged laboratory results (69%), radiology reports (65%), and clinical care summaries (64%) with outside providers. Almost six in ten hospitals electronically exchanged medication history (58%) with outside providers.

In March 2010, The State Health Information Exchange Program funded states’ efforts to rapidly build capacity for exchanging health information across the health care system both within and across states (9). Since 2010, exchange of health information by hospitals increased at the state level, such that by 2014, a majority of hospitals in most states electronically exchanged key clinical information with outside providers, including clinical care summaries. In contrast, less than half of states had a majority of hospitals electronically exchanging with outside providers in 2010, and no states had the a majority of hospitals electronically exchanging clinical care summaries with outside providers.

## Definitions

Non-federal acute care hospital: Includes acute care general medical and surgical, children’s general, and cancer hospitals owned by private/not-for-profit, investor-owned/for-profit, or state/local government and located within the 50 states and District of Columbia.
Any outside providers: Encompasses ambulatory care providers, hospitals, or both that are outside the respondent’s organization.
Hospital health information exchange: Assessed using survey questions asking respondents whether their hospital electronically exchanged or shared the following four types of clinical information: radiology reports, laboratory results, clinical care summaries, and medication lists.

Table 1 Survey questions assessing hospitals’ health information exchange activity.

Which of following patient data does your hospital electronically exchange/share with one or more of the provider types listed below? (Check all that apply)
| With Hospitals In Your System | With Hospitals Outside of Your System | With Ambulatory Providers Inside of Your System | With Ambulatory Providers Outside of Your System | Do not know
Laboratory results | □ | □ | □ | □ | □
Medication history | □ | □ | □ | □ | □
Radiology reports | □ | □ | □ | □ | □
Clinical/Summary care record in any format | □ | □ | □ | □ | □

## Data Source and Methods

Data are from the American Hospital Association (AHA) Information Technology (IT) Supplement to the AHA Annual Survey. Since 2008, ONC has partnered with the AHA to measure the adoption and use of health IT in U.S. hospitals. ONC funded the 2014 AHA IT Supplement to track hospital adoption and use of EHRs and the exchange of clinical data.

The chief executive officer of each U.S. hospital was invited to participate in the survey regardless of AHA membership status. The person most knowledgeable about the hospital’s health IT (typically the chief information officer) was requested to provide the information via a mail survey or secure online site. Non-respondents received follow-up mailings and phone calls to encourage response. The survey was fielded from November 2014 to the end of February 2015.

The survey was administered to 4,451 non-federal acute care hospitals, with a response rate of 60%. A logistic regression model was used to predict the propensity of survey response as a function of hospital characteristics, including size, ownership, teaching status, system membership, availability of a cardiac intensive care unit, urban status, and region. Hospital-level weights were derived by the inverse of the predicted propensity.

Estimates considered unreliable had a relative standard error adjusted for finite populations greater than 0.49. Responses with missing values were assigned zero values. Significant differences were tested using p < 0.05 as the threshold.

## References

1 The Office of the National Coordinator for Health IT. (2015). Connecting health and care for the nation: A shared nationwide interoperability roadmap version 1.0. Accessed March 30, 2015 at: http://www.healthit.gov/sites/default/files/nationwide-interoperability-roadmap-draft-version-1.0.pdf
2 The Office of the National Coordinator for Health IT. (2014). Federal Health IT Strategic Plan 2015–2020. Accessed March 30, 2015 at: http://www.healthit.gov/sites/default/files/federal-healthIT-strategic-plan-2014.pdf
3 Swain M, Charles D, & Furukawa MF. (2014). Health information exchange among U.S. non-federal acute care hospitals: 2008–2013. ONC Data Brief, no.17. Office of the National Coordinator for Health Information Technology: Washington DC. Accessed March 30 2015 from: http://healthit.gov/sites/default/files/oncdatabrief17_hieamonghospitals.pdf
4 Burwell SM. (2015). Setting value-based payment goals--HHS efforts to improve U.S. health care. N Engl J Med, 372(10), 897–9.25622024
5 Centers for Medicare & Medicaid Services. [Medicare and Medicaid] EHR Incentive Programs. Available from: https://www.cms.gov/ehrincentiveprograms.
6 Furukawa MF1, Patel V, Charles D, Swain M, & Mostashari F. (2013). Hospital electronic health information exchange grew substantially in 2008–12. Health Aff (Millwood), 32(8):1346–54.23918477
7 Vest JR. (2010). More than just a question of technology: factors related to hospitals’ adoption and implementation of health information exchange. Int J Med Inform, 79(12), 797–806.20889370
8 Miller AR & Tucker C. (2014). Health information exchange, system size and information silos. J Health Econ, 33, 28–4.24246484
9 The Office of the National Coordinator for Health IT. State Health Information Exchange. Available from: http://healthit.gov/policy-researchers-implementers/state-health-information-exchange

## Appendix

Table A1 Percent of non-federal acute care hospitals that electronically exchanged health information with outside ambulatory providers or hospitals by U.S. state: 2010 and 2014.

State | 2010 % | 2014 % | Percent Change
United States | 44 | 76 | 73
Alabama | 37 | 76 | 105
Alaska | 60 | 86 | 43
Arizona | 37 | 79 | 114
Arkansas | 50 | 79 | 58
California | 36^§^ | 68^§^ | 89
Colorado | 65^†^ | 80 | 23
Connecticut | 42 | 77 | 83
Delaware | 61 | 100^†^ | 64
District of Columbia | 43 | 66 | 53
Florida | 50 | 82^†^ | 64
Georgia | 40 | 83^†^ | 108
Hawaii | 63 | 91^†^ | 44
Idaho | 47 | 58^§^ | 23
Illinois | 39^§^ | 79 | 103
Indiana | 60^†^ | 85^†^ | 42
Iowa | 36^§^ | 66^§^ | 83
Kansas | 31^§^ | 60^§^ | 94
Kentucky | 42 | 82^†^ | 95
Louisiana | 25^§^ | 77 | 208
Maine | 62^†^ | 67 | 8
Maryland | 53^†^ | 88^†^ | 66
Massachusetts | 64^†^ | 85^†^ | 33
Michigan | 52^†^ | 78 | 50
Minnesota | 42^§^ | 83^†^ | 98
Mississippi | 25^§^ | 55^§^ | 120
Missouri | 48^†^ | 65^§^ | 35
Montana | 45 | 63 | 40
Nebraska | 40 | 69 | 73
Nevada | 55 | 42^§^ | (−24)
New Hampshire | 64^†^ | 88^†^ | 38
New Jersey | 38 | 83^†^ | 118
New Mexico | 31 | 82 | 165
New York | 59^†^ | 76 | 29
North Carolina | 45 | 78 | 73
North Dakota | 39 | 85 | 118
Ohio | 53^†^ | 86^†^ | 62
Oklahoma | 49 | 72 | 47
Oregon | 53 | 87^†^ | 64
Pennsylvania | 52^†^ | 87^†^ | 67
Rhode Island | 67^†^ | 100^†^ | 49
South Carolina | 44 | 81 | 84
South Dakota | 40 | 80 | 100
Tennessee | 40 | 69 | 73
Texas | 24^§^ | 66^§^ | 175
Utah | 51 | 76 | 49
Vermont | 43 | 80 | 86
Virginia | 44 | 93^†^ | 111
Washington | 58^†^ | 70 | 21
West Virginia | 36 | 71 | 97
Wisconsin | 62^†^ | 80 | 29
Wyoming | 47 | 67 | 43

NOTES:

* Estimate does not meet standards of reliability

† Significantly higher than national average (p < 0.05)

§ Significantly lower than national average (p < 0.05)

Any Outside Exchange refers to exchange with ambulatory care providers or hospitals outside their organization.

SOURCE: ONC/American Hospital Association (AHA), AHA Annual Survey Information Technology Supplement.

Table A2 Percent of non-federal acute care hospitals that electronically exchanged laboratory results, radiology reports, clinical care summaries, and medication history with any outside providers: 2008 to 2014.

Data Type | 2008 | 2009 | 2010 | 2011 | 2012 | 2013 | 2014
Laboratory Results | 35 | 39^†^ | 38 | 43^†^ | 53^†^ | 57^†^ | 69^†^
Radiology Reports | 37 | 42^†^ | 39^§^ | 45^†^ | 52^†^ | 55^†^ | 65^†^
Clinical Care Summaries | 25 | 26 | 22^§^ | 27^†^ | 35^†^ | 42^†^ | 64^†^
Medication History | 21 | 23 | 21^§^ | 26^†^ | 33^†^ | 37^†^ | 58^†^

NOTES:

† Significantly above from previous year (p < 0.05)

§ Significantly below from previous year (p < 0.05)

SOURCE: ONC/American Hospital Association (AHA), AHA Annual Survey Information Technology Supplement.

Table A3 Percent of non-federal acute care hospitals that electronically exchanged clinical care summaries with outside ambulatory providers or hospitals by U.S. state: 2010 and 2014.

State | 2010 | 2014 | Percent Change
United States | 22 | 64 | 191
Alabama | 18 | 71 | 294
Alaska | 18 | 49 | 172
Arizona | 17 | 75 | 341
Arkansas | 36^†^ | 59 | 64
California | 14^§^ | 64 | 357
Colorado | 41^†^ | 76^†^ | 85
Connecticut | 23 | 68 | 196
Delaware | 21 | 80 | 281
District of Columbia | 11^§^ | 48 | 336
Florida | 33^†^ | 75^†^ | 127
Georgia | 13^§^ | 80^†^ | 515
Hawaii | 23 | 65 | 183
Idaho | 18 | 42^§^ | 133
Illinois | 22 | 62 | 182
Indiana | 28^†^ | 74^†^ | 164
Iowa | 17^§^ | 60 | 253
Kansas | 10^§^ | 49^§^ | 390
Kentucky | 20 | 64 | 220
Louisiana | 16 | 63 | 294
Maine | 28^†^ | 51 | 82
Maryland | 30^†^ | 72 | 140
Massachusetts | 27 | 74 | 174
Michigan | 20 | 70 | 250
Minnesota | 27^†^ | 78^†^ | 189
Mississippi | 19 | 55 | 189
Missouri | 35^†^ | 34^§^ | (−3)
Montana | 22 | 61 | 177
Nebraska | 18 | 55 | 206
Nevada | 22 | 42^§^ | 91
New Hampshire | 32^†^ | 88^†^ | 175
New Jersey | 21 | 72 | 243
New Mexico | 20 | 30^§^ | 50
New York | 28^†^ | 61 | 118
North Carolina | 31^†^ | 67 | 116
North Dakota | 6^§^ | 85^†^ | 1,317
Ohio | 30^†^ | 77^†^ | 157
Oklahoma | 21 | 45^§^ | 114
Oregon | 12^§^ | 79^†^ | 558
Pennsylvania | 24 | 73^†^ | 204
Rhode Island | 0^§^ | 83 | 8,300
South Carolina | 19 | 74 | 289
South Dakota | 36^†^ | 80^†^ | 122
Tennessee | 24 | 53^§^ | 121
Texas | 12^§^ | 56^§^ | 367
Utah | 22 | 64 | 191
Vermont | 8^§^ | 80 | 900
Virginia | 20 | 85^†^ | 325
Washington | 30 | 65 | 117
West Virginia | 23 | 59 | 157
Wisconsin | 43^†^ | 72^†^ | 67
Wyoming | 6^§^ | 40^§^ | 567

NOTES:

* Estimate does not meet standards of reliability

† Significantly higher than national average (p < 0.05)

§ Significantly lower than national average (p < 0.05)

Any Outside Exchange refers to exchange with ambulatory care providers or hospitals outside their organization.

SOURCE: ONC/American Hospital Association (AHA), AHA Annual Survey Information Technology Supplement.