# 23 Adoption of Electronic Health Record Systems among U.S. Non-Federal Acute Care Hospitals: 2008–2014

The Health Information Technology for Economic and Clinical Health (HITECH) Act of 2009 directed the Office of the National Coordinator for Health Information Technology (ONC) to promote the adoption and meaningful use of electronic health records (EHRs). In addition, the adoption and increased use of health IT products is a keystone objective of the Federal Health IT Strategic Plan (1). This brief describes trends in adoption of EHR systems among non-federal acute care hospitals from 2008 to 2014. It tracks both the adoption of Basic EHR systems and the possession of EHR technology certified to meet federal requirements. Basic EHR adoption represents a minimum use of core functionality determined to be essential to an EHR system (see Table A1). This brief refers to Basic EHR adoption with clinical notes unless otherwise stated. A certified EHR is EHR technology that meets the technological capability, functionality, and security requirements adopted by the Department of Health and Human Services.

## Three out of Four Hospitals have a Basic EHR System.

Figure 1 Percent of non-Federal acute care hospitals with adoption of at least a Basic EHR with notes system and possession of a certified EHR: 2008–2014

NOTES: Basic EHR adoption requires the EHR system to have a set of EHR functions defined in Table A1. A certified EHR is EHR technology that meets the technological capability, functionality, and security requirements adopted by the Department of Health and Human Services. Possession means that the hospital has a legal agreement with the EHR vendor, but is not equivalent to adoption.

*Significantly different from previous year (p < 0.05).

This figure contains two line charts. The first describes adoption of Basic EHR systems from 2008 to 2013 (2008, 9.4; 2009, 12.2; 2010, 15.6; 2011, 27.6; 2012, 44.4; 2013, 59.4; 2014 75.5). The measures for 2009, 2010, 2011, 2012, 2013, and 2014 are marked as significantly different from the previous year. The second line describes adoption of certified EHR systems from 2011 to 2013 (2011, 71.9; 2012, 85.2; 2013, 94.0; 2014, 96.9). The measures for 2012 and 2013 are marked as significantly different from the previous year.

SOURCE: ONC/American Hospital Association (AHA), AHA Annual Survey Information Technology Supplement

★ In 2014, 3 out of 4 (76%) hospitals had adopted at least a Basic EHR system. This represents an increase of 27% from 2013 and an eight-fold increase since 2008.
★ Nearly all reported hospitals (97%) possessed a certified EHR technology in 2014, increasing by 35% since 2011.

## For all states, at least half of hospitals adopted a Basic EHR.

Table 1 Percent of non-federal acute care hospitals with adoption of at least a Basic EHR system by U.S. State, 2014.

State | Basic EHR, % | n (N)
United States | 75.5 | 2682 (4451)
Alabama | 72.5 | 35(89)
Alaska | 76.1 | 7(21)
Arizona | 88.6^†^ | 31(62)
Arkansas | 91.1^†^ | 35(71)
California | 71.6 | 170(325)
Colorado | 81.7^†^ | 50(71)
Connecticut | 81.2 | 22(29)
Delaware | 100.0^†^ | 5(6)
District of Columbia | 67.5 | 6(8)
Florida | 87.0^†^ | 119(182)
Georgia | 82.3^†^ | 66(130)
Hawaii | 54.8^§^ | 12(22)
Idaho | 69.5 | 19(38)
Illinois | 85.0^†^ | 126(177)
Indiana | 83.1^†^ | 61(107)
Iowa | 74.9 | 85(117)
Kansas | 60.0^§^ | 92(125)
Kentucky | 65.1^§^ | 60(96)
Louisiana | 75.3 | 42(98)
Maine | 79.1 | 19(34)
Maryland | 90.7^†^ | 33(45)
Massachusetts | 76.9 | 36(62)
Michigan | 71.7 | 83(128)
Minnesota | 84.7^†^ | 124(128)
Mississippi | 75.6 | 25(90)
Missouri | 68.5^§^ | 111(111)
Montana | 70.6 | 27(54)
Nebraska | 66.9 | 48(84)
Nevada | 63.6 | 13(30)
New Hampshire | 71.7 | 17(26)
New Jersey | 70.0 | 44(64)
New Mexico | 73.4 | 18(32)
New York | 72.5 | 110(170)
North Carolina | 78.4 | 60(106)
North Dakota | 81.7 | 14(41)
Ohio | 67.5^§^ | 100(154)
Oklahoma | 68.7 | 47(105)
Oregon | 81.4 | 36(59)
Pennsylvania | 72.4 | 107(154)
Rhode Island | 82.6 | 6(10)
South Carolina | 68.1^†^ | 26(58)
South Dakota | 95.1 | 22(51)
Tennessee | 77.9 | 52(114)
Texas | 71.7^§^ | 231(342)
Utah | 77.5 | 21(44)
Vermont | 83.1 | 5(14)
Virginia | 93.2^†^ | 51(80)
Washington | 77.4 | 32(89)
West Virginia | 49.6^§^ | 24(49)
Wisconsin | 77.4 | 82(125)
Wyoming | 67.9 | 15(24)

NOTES: Basic EHR adoption requires the EHR system to have a set of EHR functions defined in Table A1.

n = survey respondents; N = hospitals surveyed. All estimates met standards for reliability.

† Significantly higher than national average

§ Significantly lower than national average (p < 0.05)

SOURCE: ONC/AHA, AHA Annual Survey Information Technology Supplement

★ State rates of hospital adoption of at least a Basic EHR system ranged from 50% to 100%.
★ Delaware (100%), South Dakota (95%), and Virginia (93%) had the highest percent of hospitals with adoption of at least a Basic EHR system.
★ West Virginia (50%), Hawaii (55%), and Kansas (60%) had the lowest percent of hospitals with adoption of at least a Basic EHR system.

## State adoption rates have increased from 2008 to 2014.

Figure 2 State percent of non-federal acute care hospitals with adoption of at least a Basic EHR system compared with prior years.

NOTES: Basic EHR adoption requires the EHR system to have at least a basic set of EHR functions, including clinician notes, as defined in Table A1. Estimates for states shaded gray did not meet the standards for reliability (NR). See the Table A2 for a complete list of 2008 and 2011 hospital adoption by state.

This figure contains three heat maps of the United States: one for 2008, 2011, and 2014. Each describes the percentage of Basic EHR adoption rates for each state. The legend ranges include Not Reliable Estimate,™ 0-19%™, 20-39,™ 40-59%,™ 60-79%,™ and 80-100%.™ The maps show large increases in Basic EHR adoption by state from 2011 to 2014.

SOURCE: ONC/AHA, AHA Annual Survey Information Technology Supplement

★ In 2008, hospital adoption of at least a Basic EHR system was above 20% in only 2 states (Connecticut and New Mexico).
★ Three years later, hospital adoption of at least a Basic EHR system was above 20% in 32 states and above 40% in 7 states.
★ In 2014, hospital adoption of at least a Basic EHR system was above 60% in all but 2 states (Hawaii and West Virginia), and above 80% in 17 states.

## Trends in EHR adoption show increasing use of advanced functionality.

Figure 3 Percent of non-federal acute care hospitals with adoption of EHR systems by level of functionality: 2008-2014.

NOTES: Definitions of Basic EHR and Comprehensive EHR systems are reported in Table A1.

*Significantly different from previous year (p < 0.05).

This figure is a stacked bar chart describing the hospital adoption of EHR systems by type of system adopted. In 2008, 1.6% adopted comprehensive EHR systems, 7.8% adopted Basic EHR systems with notes, and 4.0% adopted Basic EHR systems without notes. The total was 13.4%. In 2009, 2.8% adopted comprehensive EHR systems, 9.4% adopted Basic EHR systems with notes, and 3.9% adopted Basic EHR systems without notes. The total was 16.1%. In 2010, 3.6% adopted comprehensive EHR systems, 12.0% adopted Basic EHR systems with notes, and 3.5% adopted Basic EHR systems without notes. The total was 19.1%. In 2011, 8.8% adopted comprehensive EHR systems, 18.8% adopted Basic EHR systems with notes, and 7.2% adopted Basic EHR systems without notes. The total was 34.8%. In 2012, 16.9% adopted comprehensive EHR systems, 27.6% adopted Basic EHR systems with notes, and 11.5% adopted Basic EHR systems without notes. The total was 55.9%. In 2013, 25.7% adopted comprehensive EHR systems, 33.7% adopted Basic EHR systems with notes, and 10.9% adopted Basic EHR systems without notes. The total was 60.3%. In 2014, 34.4% adopted comprehensive EHR systems, 41.1% adopted Basic EHR systems with notes, and 7.7% adopted Basic EHR systems without notes. The total was 83.2%.All measures after 2008 except for the Basic EHR system without notes in 2013 were marked as significantly different from the previous year.

SOURCE: ONC/AHA, AHA Annual Survey Information Technology Supplement.

★ Fewer hospitals are using Basic EHRs without Clinician Notes, while the systems with more advanced functionality have increased significantly.
★ Hospital adoption of Comprehensive EHR systems has increased eleven-fold since 2009, rising to a third (34.4%) of hospitals in 2014.

## Summary

Adoption of EHR systems by non-federal acute care hospitals has steadily increased since HITECH. Basic EHR adoption represents a minimum use of core functionality determined to be essential to an EHR system (2). In 2014, 3 in 4 (76%) non-federal acute care hospitals had adopted at least a Basic EHR system with clinician notes. This represents a 27% increase from the previous year and a more than eight-fold increase in EHR adoption since 2008. At 16 percentage points higher than 2013, this is the second highest increase in adoption since 2012 (17 percentage points).

Moreover, since the passage of the HITECH Act in 2009, state EHR adoption rates have increased. EHR adoption rates increased from only 2 states reporting rates higher than 20% to all states reporting rates 50% or higher by 2014. Furthermore, only 2 states currently have adoption rates below 60%.

In addition to growth in EHR adoption overall, hospital adoption of technology with advanced functionality increased significantly. While fewer hospitals used Basic EHR systems without clinician notes, significantly more adopted systems with clinician notes. Additionally, over a third of hospitals were using more advanced EHR functionality. Hospital adoption of Comprehensive EHR systems has increased more than eleven-fold in the last five years.

Finally, a vast majority of acute care hospitals (97%) possessed EHR technology certified to meet federal requirements. These hospitals should have the technology needed to meet EHR Incentive Program objectives. These systems are also certified to be secure and able to work with other certified systems to share information. Thus, the increase in the rate of adoption for certified EHR technology shed a positive light on hospitals’ progress towards the interoperable exchange of health information.

## Definitions

Non-federal acute care hospital: Includes acute care general medical and surgical, general children’s, and cancer hospitals owned by private/not-for-profit, investor-owned/for-profit, or state/local government and located within the 50 states and District of Columbia. The inclusion of children’s general and cancer hospitals makes this definition different from previous peer-reviewed research (3). However, it is more consistent with the population of hospitals eligible for federal health IT adoption incentives.
Adoption of Basic EHR: Table A1 defines the electronic functions required for hospital adoption of a Basic or Comprehensive EHR system, which a consensus expert panel established (2). Basic EHR adoption requires that each function be implemented in at least one unit in the hospital. However, Comprehensive EHR adoption requires that each function be implemented in all units.
  Because the panel disagreed on the need to include physician notes and nursing assessments to classify a Basic system, so they developed two definitions of Basic EHR adoption (Basic EHR without Notes and Basic EHR with Notes) (2). Since the first stage of the CMS EHR Incentive Program did not require clinician notes, an earlier brief reported Basic EHR without Clinician Notes (4). However, clinician notes are now a requirement for the second stage (5), the definition of Basic EHR in this brief includes clinician notes as a requirement for at least a Basic EHR system.
Possession of Certified EHR: A certified EHR is EHR technology that meets the technological capability, functionality, and security requirements adopted by the Department of Health and Human Services. This includes the capability to securely work with other certified EHR systems to share information (interoperability). “Possession” of certified EHR technology is considered to be either the physical possession of the medium on which a certified EHR system resides or a legally enforceable right by a health care provider to access and use, at its discretion, the capabilities of a certified EHR system.

## Data Source and Methods

Data are from the American Hospital Association (AHA) Information Technology (IT) Supplement to the AHA Annual Survey. Since 2008, ONC has partnered with the AHA to measure the adoption and use of health IT in U.S. hospitals. ONC funded the 2014 AHA IT Supplement to track hospital adoption and use of EHRs and the exchange of clinical data.

The chief executive officer of each U.S. hospital was invited to participate in the survey regardless of AHA membership status. The person most knowledgeable about the hospital’s health IT (typically the chief information officer) was requested to provide the information via a mail survey or secure online site. Non-respondents received follow-up mailings and phone calls to encourage response. The survey was fielded from November 2014 to the end of February 2015.

This analysis consisted of non-federal, acute care hospitals, including children’s and cancer hospitals. Differences in the estimates in this brief from a prior study reporting Basic EHR adoption with clinician notes (6) are due to the inclusion of children’s and cancer hospitals and small differences in the calculation of hospital-level weights.

The response rate for non-federal acute care hospitals was 60%. A logistic regression model was used to predict the propensity of survey response as a function of hospital characteristics, including size, ownership, teaching status, system membership, availability of a cardiac intensive care unit, urban status, and region. Hospital-level weights were derived by the inverse of the predicted propensity.

Estimates considered unreliable had a relative standard error adjusted for finite populations greater than 0.49. Responses with missing values were assigned zero values. Significant differences were tested using p < 0.05 as the threshold.

## References

1 “Federal Health IT Strategic Plan 2015–2020,” Office of the National Coordinator for Health Information Technology, 2014, page 2. Available at http://www.healthit.gov/sites/default/files/federal-healthIT-strategic-plan-2014.pdf.
2 Blumenthal D, DesRoches CM, Donelan K, Ferris TG, Jha AK, Kaushal R, Health Information Technology in the United States: The Information Base for Progress. Princeton, NJ: Robert Wood Johnson Foundation; 2006.
3 DesRoches CM, Worzala C, Joshi MS, Kralovec PD, Jha AK. “Small, Nonteaching, and Rural Hospitals Continue to be Slow in Adopting Electronic Health Record Systems.” Health Affairs. 31(5): 1092–1099; 2012.22535503
4 Charles D, Furukawa MF, Hufstader M. “Electronic Health Record Systems and Intent to Attest to Meaningful Use among Non-federal Acute Care Hospitals in the United States: 2008–2011” ONC Data Brief, no 1. Washington, DC: Office of the National Coordinator for Health Information Technology. February 2012.
5 Centers for Medicare & Medicaid Services. [Medicare and Medicaid] EHR Incentive Programs. Available form: https://www.cms.gov/ehrincentiveprograms.
6 Jha AK, DesRoches CM, Campbell EG, Donelan K, Rao SR, Ferris TG, Shields A, Rosenbaum S, Blumenthal D. Use of Electronic Health Records in U.S. Hospitals. New England Journal of Medicine. 360(16): 1628–38; 2009.19321858

## Appendix

Table A1 Electronic Functions Required for Hospital Adoption of Basic or Comprehensive EHR Systems

EHR Functions Required | Basic EHR without Clinician Notes | Basic EHR with Clinician Notes | Comprehensive EHR
Electronic Clinical Information
Patient demographics | ★ | ★ | ★
Physician notes | | ★ | ★
Nursing assessments | | ★ | ★
Problem lists | ★ | ★ | ★
Medication lists | ★ | ★ | ★
Discharge summaries | ★ | ★ | ★
Advance directives | | | ★
Computerized Provider Order Entry
Lab reports | | | ★
Radiology tests | | | ★
Medications | ★ | ★ | ★
Consultation requests | | | ★
Nursing orders | | | ★
Results Management
View lab reports | ★ | ★ | ★
View radiology reports | ★ | ★ | ★
View radiology images | | | ★
View diagnostic test results | ★ | ★ | ★
View diagnostic test images | | | ★
View consultant report | | | ★
Decision Support
Clinical guidelines | | | ★
Clinical reminders | | | ★
Drug allergy results | | | ★
Drug-drug interactions | | | ★
Drug-lab interactions | | | ★
Drug dosing support | | | ★

NOTES: Basic EHR adoption requires each function to be implemented in at least one clinical unit, and Comprehensive EHR adoption requires each function to be implemented in all clinical units

Table A2 Percent of non-federal acute care hospitals with adoption of at least a Basic EHR system by U.S. State, 2008 & 2011.

State | 2008 Basic EHR, % | n (N) | State | 2011 Basic EHR, % | n (N)
United States | | | United States
Alabama | 9% | 34(99) | Alabama | 22% | 44(95)
Alaska | 0% | 7(21) | Alaska | NR | 13(22)
Arizona | 14% | 31(60) | Arizona | 17% | 31(62)
Arkansas | 9% | 53(75) | Arkansas | 32% | 40(72)
California | 9% | 179(343) | California | 22% | 153(333)
Colorado | 11% | 41(70) | Colorado | 30% | 42(72)
Connecticut | 22% | 24(31) | Connecticut | 22% | 22(30)
Delaware | 0% | 4(6) | Delaware | 39% | 5(6)
District of Columbia | NR | 5(9) | District of Columbia | 37% | 8(9)
Florida | 11% | 96(186) | Florida | 51% | 93(183)
Georgia | 5% | 78(140) | Georgia | 15% | 53(139)
Hawaii | NR | 11(22) | Hawaii | NR | 9(23)
Idaho | NR | 24(39) | Idaho | 19% | 24(39)
Illinois | 9% | 130(185) | Illinois | 35% | 131(180)
Indiana | 11% | 70(106) | Indiana | 19% | 66(107)
Iowa | 2% | 79(117) | Iowa | 35% | 83(117)
Kansas | 0% | 76(122) | Kansas | 19% | 102(123)
Kentucky | 6% | 67(97) | Kentucky | 24% | 58(98)
Louisiana | 8% | 58(108) | Louisiana | 14% | 48(101)
Maine | 3% | 29(36) | Maine | 20% | 24(36)
Maryland | 16% | 37(46) | Maryland | 28% | 39(46)
Massachusetts | 9% | 35(71) | Massachusetts | 37% | 39(67)
Michigan | 14% | 103(133) | Michigan | 31% | 87(133)
Minnesota | 17% | 80(128) | Minnesota | 44% | 127(131)
Mississippi | 8% | 39(90) | Mississippi | 17% | 37(88)
Missouri | 9% | 69(113) | Missouri | 35% | 113(113)
Montana | 6% | 33(54) | Montana | 15% | 31(54)
Nebraska | 6% | 50(83) | Nebraska | 19% | 52(84)
Nevada | 0% | 11(29) | Nevada | 36% | 13(30)
New Hampshire | 4% | 23(26) | New Hampshire | 29% | 14(26)
New Jersey | 16% | 40(66) | New Jersey | 11% | 41(63)
New Mexico | 22% | 16(31) | New Mexico | 23% | 16(29)
New York | 11% | 120(190) | New York | 26% | 118(177)
North Carolina | 11% | 79(109) | North Carolina | 24% | 76(111)
North Dakota | NR | 20(42) | North Dakota | NR | 15(42)
Ohio | 4% | 115(157) | Ohio | 20% | 96(158)
Oklahoma | 15% | 56(103) | Oklahoma | 14% | 39(102)
Oregon | 17% | 30(57) | Oregon | 42% | 25(58)
Pennsylvania | 8% | 111(163) | Pennsylvania | 30% | 109(158)
Rhode Island | NR | 6(11) | Rhode Island | 55% | 9(11)
South Carolina | 7% | 39(59) | South Carolina | 27% | 24(57)
South Dakota | 11% | 47(51) | South Dakota | 17% | 27(51)
Tennessee | 6% | 61(114) | Tennessee | 21% | 49(116)
Texas | 9% | 215(346) | Texas | 20% | 175(349)
Utah | NR | 20(41) | Utah | NR | 8(41)
Vermont | 15% | 13(14) | Vermont | 45% | 7(14)
Virginia | 15% | 52(80) | Virginia | 53% | 40(79)
Washington | 7% | 46(85) | Washington | 38% | 51(85)
West Virginia | 7% | 38(50) | West Virginia | 23% | 27(50)
Wisconsin | 10% | 85(122) | Wisconsin | 47% | 73(121)
Wyoming | 10% | 20(24) | Wyoming | 21% | 15(24)

NOTES: Basic EHR adoption requires the EHR system to have a set of EHR functions defined in Table A1.

n = survey respondents; N = hospitals surveyed. NR = estimate does not meet standards for reliability.

SOURCE: ONC/AHA, AHA Annual Survey Information Technology Supplement