# 19 Physician-Reported Safety and Quality Impacts of Electronic Health Record Use

There are widespread hopes and increasing evidence that expanded use of electronic health records (EHRs) will improve health care quality and patient safety.^1,2,3^ These improvements may be enabled by EHR functionalities such as those that provide preventive care reminders, accurate patient information when needed, and clinical decision support that assists with diagnoses and chronic care management.^4^ On the other hand, there are concerns that EHRs could present threats to patient safety resulting from complex data interfaces, poor user-interface design or poor workflow implementation.^5^ This brief uses data from the 2013 National Ambulatory Medical Care Physician Workflow Survey to assess physician-reported impacts of EHR use - both positive and negative - on health care quality and patient safety related outcomes.

## Three times as many physicians reported that their EHR prevented a potential medication error than caused one.

Figure 1 Proportion of physicians using EHRs who reported that EHR use led to positive or negative impacts associated with medication and laboratory alerts and reminders, 2013.

This figure shows a horizontal bar chart of physician reported positive and negative impacts associated with EHR use and medication and laboratory alerts and reminders. The two lowest bars represent the negative impacts associated with EHR use: 15% of physicians using an EHR reported that use of their EHR led to potential medication error and 15% of physicians using an EHR led to an inadvertent selection of the wrong medication or laboratory order from a list. The next 3 bars relate to individual questions from the survey that asked about positive impacts associated with EHR use: 29% of physicians who used EHRs reported that their EHR helped order fewer tests due to better availability of lab results; 34% of physicians who used EHRs reported that the EHR helped identify needed lab tests such as HbA1c or LDL; 45% of physicians who used EHRs reported that the EHR alerted them to a potential medication error; 51% of physicians who used EHRs reported that the EHR alerted them to critical laboratory values.

SOURCE: 2013 National Ambulatory Medical Care Survey Physician Workflow Survey. See Table A1 for question details.

★ Half of physicians using an EHR reported that the system alerted them to critical laboratory values.

## Almost half of all physicians using EHRs were reminded to provide preventive care by their EHRs.

Figure 2 Proportion of physicians using EHRs who reported that EHR use led to positive or negative impacts associated with general alerts and reminders, 2013.

This figure is a horizontal bar graph showing positive and negative impacts of EHR use associated with general alerts and reminders. The negative impact is that 14% of physicians who used EHRs reported that their EHR led them to overlook something important because they received too many alerts. There are two individual questions representing the positive impacts: 39% of physicians using EHRs reported that their EHR reminded them to provide care that meets clinical guidelines for patients with chronic conditions and 47% of physicians using EHRs reported that their EHRs reminded them to provide preventive care such as vaccine and cancer screening.

SOURCE: 2013 National Ambulatory Medical Care Survey Physician Workflow Survey. See Table A1 for question details.

★ Four in ten physicians using EHRs reported receiving reminders about chronic condition clinical care guidelines from their EHRs.
★ Fourteen percent of physicians with EHRs reported that their EHR caused them to overlook something because they received too many alerts.

## The majority of physicians using EHRs said that their EHR facilitated direct communication with other providers.

Figure 3 Proportion of physicians using EHRs who reported that EHR use led to positive or negative impacts associated with EHR-facilitated communication, 2013.

This figure is a horizontal bar graph showing the proportion of physicians using EHRs who reported that EHR use led to positive or negative impacts associated with EHR-facilitated communication. There is one negative impact depicted on the graph: 39% of physicians using EHRs reported that their EHR led to less effective communication during patient visits. There are four individual positive measures reported here: among physicians using EHRs, 30% reported that their EHR facilitated direct communication with a patient (e.g. email or secure messaging), 42% reported their EHR helped follow-up on a referral, 52% reported their EHR helped them order a referral, and 58% reported that their EHR facilitated direct communication with other providers who are part of the care team.

SOURCE: 2013 National Ambulatory Medical Care Survey Physician Workflow Survey. See Table A1 for question details.

★ A majority of physicians using EHRs said that their EHR facilitated direct communication with other providers (58%) and helped with referrals (52%).
★ Provider-to-patient communication facilitated through EHR use was less common: 30% of physicians using EHRs reported that their EHR facilitated direct communication with patients through email or secure messaging.
★ Almost 4 in 10 physicians who used EHRs said that their use of the technology led to less effective communication during patient visits.

## Physicians using EHRs that met Meaningful Use criteria were significantly more likely to report safety improvements associated with EHRs than physicians without that technology.

Table 1 Statistically significant adjusted relative risks for improved safety and quality impacts associated with EHR use, by physician and practice characteristics, 2013.

| Any Positive Medication/Laboratory Orders & Results | Any Positive General Reminders & Alerts | Any Positive Communication
Overall percent among physicians using EHRs | 69% | 51% | 70%
Specialty
Primary care | 1.26 | 1.19 | 1.12
Other specialty (comparison group) | 1.00 | 1.00 | 1.00
Practice Size
2 physicians | -- | -- | --
3–5 physicians | -- | -- | 1.12
6–10 physicians | -- | -- | 1.12
11+ physicians | 1.14 | -- | 1.15
Solo practice (comparison group) | 1.00 | 1.00 | 1.00
Practice Ownership
Community health center | -- | -- | --
HMO, insurance plan, or other health care corp. | 1.11 | 1.23 | 1.18
Hospital or academic medical center | -- | -- | --
Physician/Group owned (comparison group) | 1.00 | 1.00 | 1.00
Participation in Delivery Reform (PCMH, ACO, or pay-for-performance)
Yes | 1.10 | 1.09 | 1.11
No (comparison group) | 1.00 | 1.00 | 1.00
EHR Technology
EHR meets MU criteria | 1.22 | 1.26 | 1.19
EHR does not meet MU criteria, or unknown (comparison group) | 1.00 | 1.00 | 1.00
Length of EHR Install
5+ years | -- | -- | 1.28
2–4 years | -- | -- | 1.19
1 year | -- | -- | --
<1 year (comparison group) | 1.00 | 1.00 | 1.00

NOTES: The regression model controlled for the characteristics listed above, as well as physician sex, age, and practice location (urban vs. rural). The characteristics without numeric values were not significantly different to the comparison group. All adjusted RRs available in Table A2.

SOURCE: 2013 National Ambulatory Medical Care Survey Physician Workflow Survey. See Table A1 for details on questions and categories.

★ When compared with physicians using EHRs that did not meet Meaningful Use criteria, physicians with meaningful use-enabled EHRs reported their systems were: 26% more likely generate general alerts and reminders that improve patient care, 22% more likely to demonstrate positive medication or laboratory impacts, and 19% more likely to enhance communication.

## Negative safety impacts associated with EHRs were fairly consistent across most categories.

Table 2 Statistically significant adjusted relative risks, by physician and practice characteristics, for areas of decreased patient safety associated with EHR use, 2013.

| Led to less effective communication during patient visits | Led you to overlook something important because you received too many alerts | Led to a potential medication error | Inadvertently led you to select the wrong medication or lab order from a list
Overall percent among physicians using EHRs | 39% | 14% | 15% | 15%
Specialty
Primary care | -- | 1.10 | 1.09 | 1.08
Other specialty (comparison group) | 1.00 | 1.00 | 1.00 | 1.00
Practice Size
2 physicians | -- | -- | -- | --
3–5 physicians | -- | -- | -- | --
6–10 physicians | -- | -- | -- | --
11+ physicians | -- | -- | -- | --
Solo practice (comparison group) | 1.00 | 1.00 | 1.00 | 1.00
Practice Ownership
Community health center | 1.28 | -- | -- | --
HMO, insurance plan, or other health care corp. | -- | -- | -- | --
Hospital or academic medical center | 1.16 | -- | -- | --
Physician/group owned (comparison group) | 1.00 | 1.00 | 1.00 | 1.00
Participation in Delivery Reform (PCMH, ACO, or pay-for-performance)
Yes | -- | -- | -- | --
No (comparison group) | 1.00 | 1.00 | 1.00 | 1.00
EHR Technology
EHR meets MU criteria | -- | 1.09 | -- | 1.06
EHR does not meet MU criteria, or unknown (comparison group) | 1.00 | 1.00 | 1.00 | 1.00
Length of EHR Install
5+ years | -- | -- | -- | --
2–4 years | -- | -- | -- | --
1 year | -- | -- | -- | --
<1 year (comparison group) | 1.00 | 1.00 | 1.00 | 1.00

NOTES: The regression model controlled for the characteristics listed above, as well as physician sex, age, practice location (urban vs. rural), and time since EHR installation. The characteristics without numeric values are not significantly different to the comparison group. All adjusted RRs available in Table A3.

SOURCE: 2013 National Ambulatory Medical Care Survey Physician Workflow Survey. Questions defined in Table A1.

★ Compared to physicians using EHRs that did not meet Meaningful Use criteria, physicians with meaningful use-enabled EHRs were 9% more likely to report overlooking something important due to too many alerts and 6% more likely to report inadvertently selecting the wrong medication or lab from a list.

## Summary

This brief highlights the many areas where patient safety and quality of care may be improved through the use of EHRs. There are, however, a small but significant percent of reports where safety and quality may be negatively impacted from EHR use.

Use of EHRs that met Meaningful Use criteria was significantly associated with all areas of improved patient safety and quality of care.

Technology alone, however, will not eliminate all patient harm or patient safety events.^6^ Consistently, physicians with EHRs participating in delivery reform (patient-centered medical homes, accountable care organizations, and pay-for-performance programs), or located in practices owned by HMOs and other insurance organizations, were more likely than their comparison groups to report EHR-associated improvements in patient safety and quality of care. These are groups that generally implement workflow changes in addition to adopting health information technology.^7^

There were not many characteristic-based differences among providers reporting negative impacts associated with EHR use. Physicians using EHRs that met Meaningful Use criteria were more likely to report potential problems stemming from selection of the incorrect medication or laboratory order due to a poorly structured list, as well as overlooking something as a result of too many alerts. The proportion of physicians using EHRs who reported these problems was 16% for poorly structured lists and 17% for overlooking something due to too many alerts.

It should be noted that the information presented here about potential safety impact caused by electronic health records are reported in isolation. That is, there are many other sources of potential patient harm. Patient safety events happen every day, with and without health information technology.^8,^ ^9^ This brief demonstrates that EHR use among physicians is associated with more positive impacts than negative.

## Definitions

Positive impacts: Includes nine questions from the Physician Workflow Survey, listed in Table A1 below with “Positive” in the “Safety Impact” column.
Negative impacts: Includes four questions from the Physician Workflow Survey, listed in Table A1 below with “Negative” in the “Safety Impact” column.
EHR meets Meaningful Use (MU) criteria: Physician indicated in the survey that the EHR technology being used at the reporting location meets the criteria for Meaningful Use (referring to the CMS EHR Incentive Program).^10^
Participation in delivery reform activities: Physician responded affirmatively to at least one of the following questions:
  - Does the reporting location participate in a certified PCMH arrangement?
  - Does the reporting location participate in a Pay-for-Performance arrangement?
  - Does the reporting location participate in an Accountable Care Organization or similar arrangement?

## Data Source and Methods

The Centers for Disease Control and Prevention conducts the NAMCS survey on an annual basis. The Physician Workflow Survey, which is the basis of the data presented here, is a supplement to the NAMCS survey. Physicians included in this survey provide direct patient care in office-based practices and community health centers; excluded are those without direct patient care (radiologists, anesthesiologists, and pathologists). Additional documentation regarding the survey is available here: http://www.cdc.gov/nchs/ahcd/ahcd_survey_instruments.htm

Questions used from the survey to assess patient safety and quality of care impacts are listed in Table A1, with corresponding category assignment and whether the question was a reflection of a positive or negative safety impact. Physicians were counted in the numerator for proportions if they indicated “Yes, within the last 30 days” in response to the question. All physicians who were actively using EHR technology at the time of the survey were included in the denominator, unless “N/A” was indicated as a response for the specific question. For any analysis based on the grouped categories, physicians were excluded only if they responded “N/A” to all questions in the category.

Adjusted relative risks were calculated using the surveyreg procedure in SAS version 9.3.^11,^ ^12^ Composite measures for the positive impacts were used in the regression models only after it was determined that the variability within each grouping’s individual questions was minimal, and that the composite measure results were similar. The multivariate regressions controlled for physician characteristics such as age, sex, and specialty; practice characteristics including practice size, participation in delivery reform (pay-for-performance, patient-centered medical home, and/or Accountable Care Organization), rural/urban location (based on the 2012 Area Resource File^13^), using the physician’s county to determine whether they were in a metropolitan area (urban) or rural (not metropolitan), and practice ownership; and EHR characteristics (length of EHR installation and whether the EHR technology meets Meaningful Use criteria).

## References

1 Health Information Technology for Economic and Clinical Health (HITECH) Act, Title XIII of Division A and Title IV of Division B of the American Recovery and Reinvestment Act of 2009 (ARRA). (2009, February 17). Pub. L. No 111–5.
2 Blumenthal, D., & Tavenner, M. (2010). The "Meaningful Use" Regulation for Electronic Health Records. N Engl J Med. 2010; 363(6): 501–504.20647183
3 Jones, SS; Rudin, RS; Perry T; Shekelle PG. Health Information Technology: An Updated Systematic Review with a Focus on Meaningful Use. Ann Intern Med. 2014; 160(1): 48–54 24573664
4 Institute of Medicine. Patient Safety: Achieving a New Standard of Care. Washington, DC: The National Academies Press, 2004.
5 Institute of Medicine. Health IT and Patient Safety: Building Safer Systems for Better Care. Washington, DC: The National Academies Press, 2012.
6 Meeks, DW; Smith MW; Taylor, L; Sittig, DF; Scott, JM; Singh, H. An Analysis of Electronic Health Record-related Patient Safety Concerns. J Am Med Inform Assoc, Published online first 23June2014.
7 Blavin, F., Ramos, C., Shah, A., & Devers, K. Lessons from the literature on electronic health record implementation. The Urban Institute, 2013.
8 James, JT. A New, Evidence-based Estimate of Patient Harms Associated with Hospital Care. J Patient Safety. 2013; 9(3): 122–128.
9 Department of Health and Human Services Office of Inspector General. Adverse Events in Hospitals: National Incidence Among Medicare Beneficiaries. OEI-06–09-00090. November, 2010.
10 Centers for Medicare and Medicaid Services. (2010). Medicare and Medicaid Electronic Health Record Incentive Program – Stage 1 Final Rule. 42 CFR Parts 412, 413, 422, and 495. Federal Register, 2010.
11 .Brumback, BA; Bouldin, ED; Zheng, HW; Cannell, MB; Andresen, EM. Testing and Estimating Model-Adjusted Effect-Measure Modification Using Marginal Structural Models and Complex Survey Data. Am J Epi. 2010; 172:1085–1091.
12 Lindquist, K. SAS FAQ: How can I estimate relative risk in SAS using proc genmod for common outcomes in cohort studies? UCLA: Statistical Consulting Group. http://www.ats.ucla.edu/stat/sas/faq/relative_risk.htm
13 Area Health Resources Files (AHRF) 2012–2013. US Department of Health and Human Services, Health Resources and Services Administration, Bureau of Health Professions, Rockville, MD.

## Acknowledgments

The authors would like to thank Jennifer King for her assistance.

## Appendix

Table A1 Selected Safety-Related Questions from the 2013 National Ambulatory Medical Care Survey, Physician Workflow Survey

Analytic Category | Positive or Negative Impact | Question Text This question is about the ways that an EHR system might affect your reporting location. Has your EHR system:
Communication: Provider-to-Patient | Positive | Facilitated direct communication with a patient (e.g., email or secure messaging)?
Communication: Provider-to-Patient | Negative | Led to less effective communication during patient visits?
Communication: Provider-to-Provider | Positive | Facilitated direct communication with other providers that are part of your care team?
Communication: Provider-to-Provider | Positive | Helped you follow-up on a referral?
Communication: Provider-to-Provider | Positive | Helped you order a referral?
General reminders / alerts | Positive | Reminded you to provide preventive care (e.g., vaccine, cancer screening)?
General reminders / alerts | Positive | Reminded you to provide care that meets clinical guidelines for patients with chronic conditions?
General reminders / alerts | Negative | Led you to overlook something important because you received too many alerts?
Medication / Laboratory Orders and Results | Positive | Alerted you to a potential medication error?
Medication / Laboratory Orders and Results | Positive | Helped you identify needed lab tests (such as HbA1c or LDL)?
Medication / Laboratory Orders and Results | Positive | Helped you order fewer tests due to better availability of lab results?
Medication / Laboratory Orders and Results | Positive | Alerted you to critical lab values?
Medication / Laboratory Orders and Results | Negative | Led to a potential medication error?
Medication / Laboratory Orders and Results | Negative | Inadvertently led you to select the wrong medication or lab order from a list?

SOURCE: 2013 National Ambulatory Medical Care Survey Physician Workflow Survey.

Table A2 Adjusted Relative Risks for Improved Patient Safety Categories, by Physician and Practice Characteristics, 2013.

| | Positive Communication Impacts | Positive General Reminders/Alerts | Positive Medication/Laboratory Orders and Results
Overall percent among physicians using EHRs | | 70% | 51% | 69%
Physician Sex | Female (vs. Male) | 1.02 | 0.99 | 0.98
Physician Age | Under 50 (vs. Over 50) | 1.04 | 1.02 | 1.05
Physician specialty | Primary Care (vs. other specialty) | 1.12^*^ | 1.19^**^ | 1.26^**^
Practice Size (compared to Solo practices) | 2 physicians | 1.06 | 1.08 | 0.97
Practice Size (compared to Solo practices) | 3–5 physicians | 1.12^*^ | 0.95 | 0.98
Practice Size (compared to Solo practices) | 6–10 physicians | 1.12^*^ | 0.99 | 1.03
Practice Size (compared to Solo practices) | 11+ physicians | 1.15^*^ | 0.95 | 1.15^*^
Practice Ownership (compared to Physician or Group owned) | HMO, insurance plan, or other health care corp. | 1.18^**^ | 1.23^*^ | 1.11^*^
Practice Ownership (compared to Physician or Group owned) | Community Health Center | 1.06 | 0.92 | 0.92
Practice Ownership (compared to Physician or Group owned) | Hospital or academic medical center | 1.07 | 0.98 | 1.05
Practice Ownership (compared to Physician or Group owned) | Other / unknown | 1.02 | 1.17 | 0.99
Participation in any delivery reform activities | Yes (vs. No) | 1.11^*^ | 1.09^*^ | 1.10^*^
Rural Area | Rural (vs. Urban) | 1.03 | 1.00 | 1.01
EHR meets MU Criteria | Yes (vs. No) | 1.19^*^ | 1.26^**^ | 1.22^**^
Length of EHR Install (compared to less than 1 year) | 1 yr | 1.12 | 1.06 | 1.15
Length of EHR Install (compared to less than 1 year) | 2–4 years | 1.19^*^ | 1.08 | 1.10
Length of EHR Install (compared to less than 1 year) | 5+ years | 1.28^*^ | 1.22 | 1.14

NOTE: This table includes the full regression results that are summarized on Table 1.

* indicates p-value of <0.05

** indicates a p-value <0.0001

SOURCE: 2013 National Ambulatory Medical Care Survey Physician Workflow Survey. Categories and associated questions defined in Table A1.

Table A3 Adjusted Relative Risks for Areas of Decreased Patient Safety, by Physician and Practice Characteristics, 2013.

| | Overlooking something because you received too many alerts | Potential medication error | Less effective communication during patient visits | Inadvertently selecting wrong medication or lab from a list
Overall percent among physicians using EHRs | | 14% | 15% | 39% | 15%
Physician sex | Female (vs. Male) | 1.04 | 1.00 | 1.01 | 1.06
Physician age | Under 50 (vs. Over 50) | 1.02 | 1.02 | 1.01 | 1.02
Physician specialty | Primary care (vs. other specialty) | 1.10^*^ | 1.09^*^ | 1.04 | 1.08^*^
Practice Size (compared to Solo practices) | 2 physicians | 1.01 | 0.93 | 0.97 | 0.97
Practice Size (compared to Solo practices) | 3–5 physicians | 1.00 | 0.99 | 1.06 | 1.06
Practice Size (compared to Solo practices) | 6–10 physicians | 1.07 | 0.99 | 1.13^*^ | 1.04
Practice Size (compared to Solo practices) | 11+ physicians | 1.05 | 0.98 | 1.01 | 1.01
Practice Ownership (compared to physician or group owned) | HMO, insurance plan, or other health care corp. | 1.02 | 0.98 | 1.04 | 1.03
Practice Ownership (compared to physician or group owned) | Community Health Center | 1.07 | 1.14 | 1.28^*^ | 1.14
Practice Ownership (compared to physician or group owned) | Hospital or academic medical center | 1.02 | 0.96 | 1.16^*^ | 1.05
Practice Ownership (compared to physician or group owned) | Other / unknown | 1.02 | 1.04 | 1.11 | 0.95
Participation in any delivery reform activities | Yes (vs. No) | 1.02 | 1.01 | 1.00 | 1.01
Rural Area | Rural (vs. Urban) | 1.02 | 1.03 | 0.92 | 1.04
Using CEHRT | Yes (vs. No) | 1.09^*^ | 1.04 | 1.10 | 1.06^*^
Length of EHR Install (compared to less than 1 year) | 1 yr | 1.04 | 1.04 | 0.99 | 1.02
Length of EHR Install (compared to less than 1 year) | 2–4 years | 1.01 | 1.04 | 0.92 | 1.04
Length of EHR Install (compared to less than 1 year) | 5+years | 0.98 | 1.01 | 0.82 | 0.96

NOTE: This table includes the full regression results that are summarized on Table 2.

* indicates p-value of <0.05.

SOURCE: 2013 National Ambulatory Medical Care Survey Physician Workflow Survey. Categories and associated questions defined in Table A1.