# 11 Regional Extension Center Nurse Practitioners and Physician Assistants: Crucial Primary Care Providers on the Path to Meaningful Use

Nurse Practitioners (NPs) and Physician Assistants (PAs) provide critical primary care in communities across the country, and are poised to expand their work as health care coverage grows to cover an estimated 33 million currently uninsured individuals^2^ and as initiatives like Medical Homes and Accountable Care Organizations take hold. At the same time, primary care provider shortfalls may increase up to 46,000 by 2020^3^, as well as current undersupply of 7,550 physicians in primary care Health Professional Shortage Areas (HPSAs)^4^. Positioned to fill some of this need, NPs and PAs are the fastest growing provider segments in primary care^5^.

Operating at the top of their license, NPs and PAs offer treatment, patient education and care coordination. These providers are fundamental to broad expansions of health care and payment reforms facilitated by Meaningful Use^6^ (MU) of health information technology (IT), electronic health records (EHR), and health information exchange (HIE).

The Office of the National Coordinator for Health Information Technology (ONC) Regional Extension Center (RECs) programs, funded through The Health Information Technology for Economic and Clinical Health (HITECH) Act of 2009^7^, coordinate and stimulate the adoption and use of health IT to transform health care delivery. Supporting providers such as physicians, NPs and PAs, RECs provide practice transformation coaching and other direct technical assistance (TA) to select, implement, and meaningfully use certified EHR technology. RECs prioritize their support to clinical settings critical to the nation’s primary care infrastructure, including small practices and those primarily serving rural and underserved communities. This brief will focus on the EHR adoption by NPs and Pas and illustrate the number and location of these providers enrolled with a REC and their progress toward meaningful use of EHRs in underserved and other high priority settings.

## Four in five NPs and PAs enrolled with an REC are live with an EHR.

Figure 1 Nurse practitioners and physician assistants at ONC Milestones.

Figure 1. A bar chart shows that 4 out of 5 Nurse Practitioners (NPs) and Physicians Assistants (PAs)who have enrolled with a REC are live with an EHR, and 23-24% are demonstrating Meaningful Use. Percentages are similar for both NPs and PAs.. Of 9,923 REC-enrolled Physicians Assistants , 60% (5,908) are enrolled but not yet live; 60% (5,908) are live but have not demonstrated Meaningful Use and 24% (2,375) have demonstrated Meaningful Use. Of 20,854 REC enrolled Nurse Practitioners, 20% (4,171) are enrolled, but not live. 57% (11,972) are live with an EHR, but have not demonstrated Meaningful Use and 23% (4,749) have demonstrated meaningful use.

SOURCE: Customer Relationship Management (CRM) Tool, maintained by the Office of Provider Adoption and Support (OPAS) at ONC. Data as of March 18, 2013.

## RECs are working with half of all primary care NPs and 44% of all primary care PAs nationwide

Figure 2 Proportion of Primary Care Nurse Practitioners enrolled with RECs by State

Figure 2. A map of the United States shows 52% of all primary care NPs and 47% of primary care PAs are working with a REC. States categorized by enrollment ranges: The following states have 26-40% of Primary Care Nurse Practitioners enrolled with RECs: Alabama, Illinois, Maryland, Massachusetts, Michigan, Missouri, Nevada, South Carolina, Tennessee, Texas, Utah, and Wisconsin. The following 41 to 50% NPs enrolled: Arizona, Arkansas, Connecticut, Georgia, Hawaii, Indiana, Kansas, Louisiana, Maine, North Carolina, Pennsylvania, Virginia, and Wyoming. The following have 51 to 70% NPs enrolled: California, Colorado, Florida, Idaho, Iowa, Kentucky, Mississippi, New Jersey, New York, North Dakota, Oklahoma, Washington, and West Virginia. The following have 71 to 100% NPs enrolled: Alaska, Delaware, Minnesota, Montana, Nebraska, New Hampshire, New Mexico, Ohio, Oregon, Rhode Island, South Dakota, and Vermont.

SOURCE: Customer Relationship Management (CRM) Tool, maintained by OPAS at ONC. Data as of March 18, 2013. Total number of primary care NPs as estimated by SK&A survey data, 2011.

★ REC enrollment ranges from 26% to 100%. 20,854 NPs are enrolled with RECs.
★ More than half of all primary care NPs (58%) in rural areas are enrolled with an REC.

Figure 3 Proportion of Primary Care Physician Assistants enrolled with RECs by State

Figure 3. A map of the Unite States showing the proportion of Primary Care Physicians Assistants enrolled with RECs by State. By enrollment ranges: The following states have 10 to 28% of Primary Care Physicians Assistants enrolled with RECs: Alabama, Arkansas, Connecticut, Illinois, Indiana, Louisiana, Massachusetts, Mississippi, Missouri, Tennessee, Texas, and Virginia The following had 29 to 42% PA enrollment: Arizona, Georgia, Hawaii, Kansas, Maryland, Michigan, Nevada, North Carolina, Oklahoma, Pennsylvania, South Carolina, Utah, and Wisconsin The following had 43 to 64% PA enrollment: California, Colorado, Florida, Iowa, Kentucky, Maine, New Jersey, New Mexico, New York, Ohio, Washington, West Virginia, and Wyoming The following had 65 to 100% PA enrollment: Alaska, Delaware, Idaho, Minnesota, Montana, Nebraska, New Hampshire, North Dakota, Oregon, Rhode Island, South Dakota, and Vermont

SOURCE: Customer Relationship Management (CRM) Tool, maintained by OPAS at ONC. Data as of March 18, 2013. Total number of primary care PAs as estimated by SK&A survey data, 2011.

★ REC enrollment of PAs ranges from 10% to 100%. 9,923 PAs are enrolled with RECs.
★ 56% of all primary care PAs in rural areas are enrolled with an REC

## Over three-quarters of all primary care NPs and 63% of all primary care PAs in primary care HPSAs are receiving REC assistance

Table 1 NP and PA REC-Enrolled Provider Distribution by State

| REC-Enrolled Nurse Practitioners | | | | | | REC-Enrolled Physician Assistants
| Enrolled in REC | % Live with EHR | % Demonstrating MU | % of All Primary Care NPs | % of Rural Primary Care NPs | % of Primary Care NPs in HPSAs | Enrolled in REC | % Live with EHR | % Demonstrating MU | % of All Primary Care PAs | % of Rural Primary Care PAs | % of Primary Care PAs in HPSAs
AK | 210 | 73% | 9% | 100%^*^ | 100%^*^ | 100%^*^ | 211 | 83% | 5% | 100%^*^ | 100%^*^ | 100%^*^
AL | 221 | 94% | 28% | 36% | 37% | 45% | 23 | 100% | 17% | 22% | 19% | 100%
AR | 244 | 68% | 27% | 51% | 68% | 79% | 8 | 50% | 13% | 10% | 11% | 35%
AZ | 483 | 81% | 21% | 50% | 97% | 100% | 253 | 77% | 17% | 41% | 86% | 58%
CA | 1,909 | 78% | 22% | 58% | 61% | 81% | 1,303 | 81% | 30% | 51% | 69% | 71%
CO | 380 | 90% | 28% | 53% | 66% | 68% | 470 | 88% | 37% | 62% | 71% | 79%
CT | 239 | 70% | 13% | 41% | 53% | 100%^*^ | 64 | 81% | 8% | 24% | 42% | 100%^*^
DC | 115 | 90% | 34% | 100%^*^ | n/a | 100%^*^ | 37 | 65% | 24% | 100%^*^ | n/a | 100%^*^
DE | 211 | 93% | 50% | 100%^*^ | 100%^*^ | 100%^*^ | 53 | 94% | 55% | 100%^*^ | 100%^*^ | 100%^*^
FL | 1,575 | 74% | 20% | 63% | 72% | 85% | 525 | 78% | 23% | 45% | 38% | 50%
GA | 594 | 81% | 15% | 47% | 54% | 72% | 253 | 88% | 15% | 40% | 43% | 52%
HI | 49 | 92% | 0% | 49% | 52% | 68% | 20 | 95% | 0% | 38% | 76% | 30%
IA | 270 | 79% | 27% | 57% | 59% | 76% | 163 | 89% | 44% | 43% | 40% | 56%
ID | 138 | 86% | 20% | 51% | 51% | 64% | 185 | 80% | 17% | 68% | 77% | 56%
IL | 340 | 90% | 35% | 29% | 32% | 75% | 122 | 85% | 29% | 18% | 27% | 31%
IN | 467 | 83% | 31% | 44% | 59% | 58% | 29 | 90% | 17% | 20% | 53% | 47%
KS | 232 | 66% | 23% | 46% | 51% | 63% | 135 | 56% | 27% | 42% | 54% | 55%
KY | 619 | 71% | 18% | 65% | 65% | 99% | 169 | 84% | 24% | 55% | 71% | 69%
LA | 279 | 77% | 39% | 42% | 37% | 64% | 19 | 79% | 42% | 15% | 22% | 20%
MA | 397 | 86% | 16% | 26% | 17% | 72% | 47 | 81% | 11% | 15% | 0% | 30%
MD | 246 | 73% | 9% | 36% | 68% | 48% | 152 | 63% | 14% | 41% | 71% | 58%
ME | 192 | 89% | 47% | 50% | 60% | 58% | 96 | 93% | 29% | 52% | 55% | 63%
MI | 330 | 85% | 31% | 34% | 53% | 51% | 276 | 90% | 41% | 30% | 46% | 55%
MN | 687 | 88% | 2% | 84% | 80% | 100%^*^ | 343 | 90% | 0% | 71% | 72% | 88%
MO | 343 | 80% | 34% | 28% | 32% | 51% | 22 | 86% | 27% | 16% | 25% | 19%
MS | 439 | 96% | 41% | 54% | 58% | 100%^*^ | 5 | 100% | 0% | 18% | 0% | 0%
MT | 150 | 87% | 49% | 73% | 68% | 91% | 159 | 91% | 35% | 100%^*^ | 71% | 100%^*^
NC | 656 | 73% | 7% | 48% | 58% | 58% | 500 | 81% | 6% | 40% | 49% | 44%
ND | 107 | 68% | 8% | 69% | 74% | 80% | 80 | 70% | 5% | 84% | 96% | 86%
NE | 196 | 86% | 6% | 71% | 85% | 100%^*^ | 248 | 77% | 5% | 67% | 77% | 61%
NH | 243 | 96% | 49% | 75% | 94% | 87% | 91 | 97% | 46% | 71% | 86% | 58%
NJ | 492 | 81% | 13% | 70% | n/a | 100%^*^ | 139 | 94% | 29% | 53% | n/a | 94%
NM | 270 | 84% | 27% | 77% | 67% | 91% | 130 | 82% | 34% | 64% | 71% | 74%
NV | 81 | 68% | 10% | 33% | 43% | 23% | 60 | 82% | 5% | 33% | 39% | 17%
NY | 1,439 | 80% | 23% | 56% | 58% | 100%^*^ | 919 | 78% | 24% | 56% | 60% | 93%
OH | 888 | 76% | 14% | 73% | 73% | 90% | 139 | 85% | 10% | 47% | 60% | 36%
OK | 223 | 84% | 36% | 64% | 67% | 93% | 144 | 92% | 27% | 38% | 49% | 52%
OR | 566 | 77% | 16% | 84% | 87% | 99% | 295 | 89% | 15% | 91% | 86% | 95%
PA | 636 | 80% | 41% | 43% | 44% | 62% | 436 | 93% | 54% | 38% | 48% | 48%
RI | 113 | 85% | 50% | 76% | n/a | 81% | 39 | 82% | 62% | 64% | n/a | 74%
SC | 260 | 82% | 23% | 40% | 57% | 47% | 71 | 80% | 17% | 29% | 58% | 54%
SD | 132 | 75% | 33% | 98% | 96% | 90% | 167 | 78% | 26% | 83% | 83% | 91%
TN | 502 | 91% | 39% | 28% | 31% | 64% | 60 | 90% | 37% | 17% | 24% | 32%
TX | 797 | 82% | 14% | 29% | 37% | 48% | 316 | 85% | 14% | 17% | 24% | 32%
UT | 119 | 93% | 34% | 35% | 56% | 50% | 109 | 92% | 31% | 37% | 19% | 44%
VA | 525 | 59% | 18% | 41% | 49% | 60% | 73 | 77% | 29% | 20% | 30% | 33%
VT | 167 | 92% | 24% | 100%^*^ | 96% | 100%^*^ | 86 | 93% | 7% | 94% | 100%^*^ | 75%
WA | 549 | 81% | 25% | 52% | 65% | 85% | 303 | 89% | 28% | 46% | 69% | 61%
WI | 317 | 82% | 13% | 41% | 56% | 75% | 157 | 86% | 8% | 33% | 44% | 60%
WV | 168 | 88% | 29% | 56% | 50% | 68% | 157 | 90% | 24% | 53% | 52% | 75%
WY | 42 | 90% | 29% | 48% | 30% | 65% | 52 | 88% | 29% | 56% | 50% | 65%
| 20,847 | 80% | 23% | 50% | 58% | 78% | 9,913 | 83% | 24% | 44% | 56% | 63%

SOURCE: Customer Relationship Management (CRM) Tool, maintained by the Office of Provider Adoption and Support (OPAS) at ONC. Excludes AS, GU, MP, PR, VI (NP n=7, PA n=10). Total number of primary care providers as estimated by SK&A survey data, 2011.

* Number of REC-enrolled providers in the area exceeds estimate of total primary care providers in the area. See Data Sources section for more information.

## NPs and PAs enrolled with an REC are more likely to be paid for AIU and MU.

Figure 4 CMS EHR Incentive Program Participation by REC enrollment status.

An illustration showing that REC enrollment increases the likelihood of AIU and MU payments to Nurse Practitioners and Physicians Assistants. REC enrolled Nurse Practitioners: Total Registered 45% (n=509); Paid for AIU 50% (n=577); Paid for MU 5% (n=54); NON-REC Enrolled Nurse Practitioners: Total Registered 74% (n=565); Paid for AIU 24% (n=183); Paid for AIU 2% (n=14). REC enrolled Physicians Assistants: Total Registered 31% (n=2,998), Paid for AIU 61% (n=6,013), Paid for MU 8% (n=814); NON-REC enrolled Physicians Assistants: Total Registered 50% (n=5,663); Paid for AIU 47% (n=5,212); Paid for MU 3% (n=312)

SOURCE: Customer Relationship Management (CRM) Tool, maintained by the Office of Provider Adoption and Support (OPAS) at ONC data as of March 18, 2013, and CMS data as of January 31, 2013.

Key Points:

★ REC-enrolled NPs and PAs have received more than $168 million in incentive funds from CMS.
★ 60% of all CMS registered PAs (n=1,902) and 47% of NPs (n=20,983) are enrolled with an REC.
★ REC-enrolled NPs are 59% more likely to be paid for CMS MU incentives than non-enrolled CMS registered NPs.
★ PAs enrolled with an REC are 61% more likely to be paid for AIU than non-REC enrolled PAs.
★ REC-enrolled PAs are 34% more likely to be paid for MU than non-REC enrolled PAs.

## NPs and PAs working in FQHCs have the highest rate of EHR adoption (87%) compared to other REC settings.

Figure 5 REC-enrolled NPs and PAs live with an EHR by practice setting.

A radar chart showing the percent of REC-enrolled NPs and PAs live with an EHR by practice setting. Figures are approximate: Critical Access Hospitals/Rural Hospitals PAs 78% NPs 78% Community Health Center Pas 79%, NPs 79% Federally Qualified Health Centers (FQHCs) PAs and NPs: 87% Other Underserved Setting PAs 85%, NPs 80% Large Practices PAs 78%, NPs 58% Public Hospitals PAs 78%, NPs 80% Rural Health Clinic PAs and NPs: 78% Small Practice/Practice Consortia PAs 85%, NPs 80% Specialty Practice PAs 60% NPs 25%

SOURCE: Customer Relationship Management (CRM) Tool, maintained by the Office of Provider Adoption and Support (OPAS) at ONC as of March 18, 2013.

Key Points:

★ Almost 40% of REC-enrolled NPs and 44% of PAs work in small provider practices or practice consortia.
★ A third of REC-enrolled NPs (34%) and PAs (31%) are located in FQHCs and other underserved settings.
★ Four in ten REC-enrolled providers located in rural health clinics are NPs and PAs.
★ Rates of demonstrating MU (REC milestone) also vary by practice setting:
  ∘ NPs range from 1% in specialty practices to 26% in FQHCs
  ∘ PAs range from 8% in large practices to 29% in small practices and practice consortiums

| Enrolled with an REC
| Number of PAs | Number of NPs
CAH/RH | 821 | 1,211
Non-FQHCCHC | 436 | 1,442
FQHC | 1,892 | 4,420
Other Underserved Setting | 1,142 | 2,580
Large Private Practice | 36 | 65
Public Hospitals | 589 | 1,694
Rural Health Clinic | 559 | 1,036
Small Private Practice & Practice Consortium | 4,408 | 8,138
Specialty Practice | 40 | 268
Total | 9,923 | 20,854

## Summary

Physician assistants and nurse practitioners are a crucial part of the safety net of the American healthcare system, especially in primary care delivery in small practice, rural and underserved settings. The Bureau of Labor Statistics (BLS) reports that employment opportunities for PAs and registered nurses will increase by 30%^8^ and 26%^9^, respectively, between 2010 and 2020. In addition, the BLS notes that advance practice nurses such as nurse practitioners “will be in high demand, particularly in medically underserved areas such as inner cities and rural areas” ^9^, and of PAs, BLS adds that “good job prospects are expected...particularly for physician assistants working in rural and medically underserved areas, as well as physician assistants working in primary care.”^8^ The data presented in this brief demonstrate that RECs have high penetration among these professionals across the country, especially in these high-need areas, and are guiding them to provide better care and promote better health through EHR adoption and meaningful use.

NPs and PAs are an integral part of the changing healthcare landscape as critical components of team-based care. With access to care being expanded to an anticipated 33 million currently uninsured people through the Affordable Care Act, NPs and PAs must transition to meaningful use of EHRs with physicians and other healthcare providers in order to meet this demand and provide better, higher quality care to their patients. CMS EHR incentive programs to help offset the cost of this transition only provide funding to assist a portion of these providers to adopt, implement and meaningfully use EHRs. At least 53% of PAs and 22% of NPs partnered with an REC are not eligible for CMS incentives. For those NPs and PAs that are eligible for incentive payments, those partnered with RECs are more likely to be paid for AIU and MU. Regardless of financial incentives, RECs partner with these key primary care providers in participating in the meaningful use movement.

Over 2,000 NPs and PAs who are not eligible for incentive payments are demonstrating meaningful use with REC assistance based on the ONC performance milestones. In addition, these providers’ high rate of REC participation and EHR adoption indicate their commitment to providing better and more comprehensive patient care through EHRs and meaningful use. However, MU demonstration among NPs and PAs is lower than the overall rate among all REC providers (23% vs. 38%). To close this gap and leverage MU to improve patient outcomes, NPs and PAs merit continued resource allocation to support their critical contributions to the nation’s primary care tapestry.

## Definitions

AIU: For the CMS EHR Incentive Medicaid Program, eligible professionals do not have to demonstrate Meaningful Use during the first year of the program. Instead, eligible professionals must attest to Adopting, Implementing or Upgrading (AIU) a certified EHR system.
Federally Qualified Health Centers: These health centers are HRSA-supported public and private non-profit healthcare organizations that meet certain CMS criteria. FQHC look-alikes are health centers that meet the CMS “health center” definition but do not receive Section 330 funding (Section 330 of the Public Health Service Act).^4,5^ The match between HRSA and ONC REC organizations is based on HRSA funded FQHC and FQHC look-alike administrative locations and REC practices.
Health Profession Shortage Area (HPSA): areas determined by Health Resources and Services Administration to have a shortage of primary medical care providers, where there are more than 3,500 patients for every one primary care physician.
Performance milestones: The performance milestones for REC providers indicate a threshold at which point RECs qualify for grant reimbursement. RECs may enroll healthcare providers regardless of their CMS EHR Incentive Program eligibility.
  Milestone 1: Signed technical assistance contract between the Regional Center and provider with receipt of any participation fees required (enrollment).
  Milestone 2: Documentation of Go-Live status on an EHR, with active quality reporting and electronic prescribing.
  Milestone 3: Demonstrates meaningful use.
Practice settings: REC-enrolled practices are assigned a setting type by REC staff. Small/Solo Practices are private practices focused on primary care with 10 or fewer providers. Practice Consortia are generally defined as formerly-small practices that have joined together under a single tax ID to streamline administrative management. Other Underserved Settings include providers serving high levels of Medicaid and medically-underserved patients who do not fit into one of the other priority setting categories. Large practices have providers with more than 10 providers. Critical Access Hospitals (CAHs) and Rural Hospital (RH) settings include providers who work at ambulatory care clinics associated with CAHs and RHs.
Rural area: Non-metropolitan counties as identified by the Office of Management and Budget Core Based Statistical Areas (CBSA).

## Data Sources

The information on enrollment with RECs and milestone achievement was obtained from the ONC Customer Relationship Management (CRM) Tool, maintained by the Office of Provider Adoption Support (OPAS) at ONC. Data represented in this brief are current as of March 18, 2013. Each REC reports milestone achievement data to ONC at time of achievement using the CRM.

Total primary care nurse practitioner and physician assistant estimates are based on data from 2011 SK&A Office-Based Provider Database.

In some states and some area types within states, the number of REC-enrolled primary care NPs and PAs exceeded the estimate of total primary care NPs and PAs from SK&A. This could be in part because the data reflect different points in time. If the NP and PA supply in these areas has grown between 2011 and 2013, RECs with high penetration among these professions may have recruited all NPs or PAs in their region, bringing the total current enrollment figure over 100% of 2011 population estimates.

Information on Centers for Medicaid and Medicare EHR Incentive Program participation status and payment amount was received from CMS and matched with ONC CRM data on the basis of the provider’s National Provider Identifier. CMS data represented in this brief are as of January 31, 2013, merged with ONC CRM data through March 18, 2013.

FQHC identification among REC-enrolled sites is documented previously^10^. Core Based Statistical Areas and primary care HPSAs identified from the Area Resource File (ARF) 2011–2012 (US Department of Health and Human Services, Health Resources and Services Administration, Bureau of Health Professions, Rockville, MD), and merged to ONC CRM providers based on practice zip code.

## References

1 Health Information Technology for Economic and Clinical Health (HITECH) Act, Title XIII of Division A and Title IV of Division B of the American Recovery and Reinvestment Act of 2009 (ARRA), Pub. L. No 111–5 (Feb. 17, 2009).
2 Congressional Budget Office. Updated Estimates for the Insurance Coverage Provisions of the Affordable Care Act. Washington, D.C.: March 2012. http://www.cbo.gov/sites/default/files/cbofiles/attachments/03-13-Coverage%20Estimates.pdf
3 U.S. Department of Health and Human Services. The physician workforce: Projections and Research into current issues affecting supply and demand. Health Resources and Services Administration. December 2008. Accessed at http://bhpr.hrsa.gov/healthworkforce/reports/physwfissues.pdf on April 10, 2013.
4 U.S. Department of Health and Human Services. Shortage designation: Health Professional Shortage Areas & Medically Underserved Areas and Populations. Health Resources and Services Administration. Accessed at http://www.hrsa.gov/shortage/ on April 10, 2013.
5 U.S. Government Accountability Office. Primary Care Professionals: Recent Supply Trends, Projections, and Valuation of Services, GAO-08–472T. Washington, D.C.: February 12, 2008. http://www.gao.gov/new.items/d08472t.pdf
6 “Medicare and Medicaid Programs; Electronic Health Record Incentive Program (Final Rule).” Federal Register 75:144 (July 28, 2010) p, 44314. http://www.gpo.gov/fdsys/pkg/FR-2010-07-28/pdf/2010–17207.pdf
7 American Recovery and Reinvestment Act of 2009, Pub. L. No. 111–5, Pub. L. No. 111–5, div. A, tit. XIII, 123 Stat. 115, 226–279 and div. B, tit. IV, 123 Stat. 115, 467–496 (2009). http://www.gpo.gov/fdsys/pkg/BILLS-111hr1enr/pdf/BILLS-111hr1enr.pdf
8 Bureau of Labor Statistics, U.S. Department of Labor, Occupational Outlook Handbook, 2012–13 Edition, Physician Assistants, on the Internet at http://www.bls.gov/ooh/healthcare/physician-assistants.htm (visited April 25, 2013).
9 Bureau of Labor Statistics, U.S. Department of Labor, Occupational Outlook Handbook, 2012–13 Edition, Registered Nurses, on the Internet at http://www.bls.gov/ooh/healthcare/registered-nurses.htm (visited April 25, 2013).
10 Heisey-Grove D, Hawkins K, Jones E, Shanks K, Lynch K. Supporting Health Information Technology Adoption in Federally Qualified Health Centers. ONC Data Brief, no. 8. Washington, DC: Office of the National Coordinator for Health Information Technology, February, 2013.

## Acknowledgements

Special thanks to Travis Broome and Vidya Sellappan of the Centers for Medicare and Medicaid Services.