# Acronyms and Abbreviations

AAI | acute asthma index
A. artemisiifolia | Ambrosia artemisiifolia
ABG | arterial blood gas
ABPA | allergic bronchopulmonary aspergillosis
ACE | angiotensin converting enzyme
ACIP | Advisory Committee on Immunization Practices (CDC)
ACT | Asthma Control Test
AHRQ | Agency for Healthcare Research and Quality
ALT | alanine aminotransferase (enzyme test of liver function)
Amb a 1 | Ambrosia artemisiifolia
AQLQ | asthma-related quality of life questionnaire
ATAQ | Asthma Therapy Assessment Questionnaire
ATS | American Thoracic Society
BDP | beclomethasone dipropionate
Bla g1 | Blattella germanica 1 (cockroach allergen)
BMD | bone mineral density
BPT | bronchial provocation test
CAMP | Childhood Asthma Management Program
CBC | complete blood count
CC | Coordinating Committee
CDC | Centers for Disease Control and Prevention
CFC | chlorofluorocarbon (inhaler propellant being phased out because it harms atmosphere)
CI | confidence interval
COPD | chronic obstructive pulmonary disease
COX-2 | cyclooxygenase (an enzyme)
CPAP | continuous positive airway pressure
CT | computer tomography
Der f | Dermatophagoides farinae (American house-dust mite)
Der p | Dermatophagoides pteronyssinus (European house-dust mite)
DEXA | dual energy x-ray absorptiometry
DHHS | U.S. Department of Health and Human Services
DPI | dry powder inhaler
EBC | exhaled breath concentrate
ECP | eosinophilic cationic protein
ED | emergency department
EIB | exercise-induced bronchospasm
EMS | emergency medical services
eNO | exhaled nitric oxide
EPR | Expert Panel Report EPR 1991, EPR 1997 (EPR—2), EPR—Update 2002, EPR—3: Full Report 2007 (this 2007 guidelines update)
ER | emergency room
ERS | European Respiratory Society
ETS | environmental tobacco smoke
FCεRI | high-affinity IgE receptor
FDA | U.S. Food and Drug Administration
FEF | forced expiratory flow
FEF_25–75_ | forced expiratory flow between 25 percent and 75 percent of the vital capacity
FeNO | fractional exhaled nitric oxide
FEV_1_ | forced expiratory volume in 1 second
FEV_6_ | forced expiratory volume in 6 seconds
FiO_2_ | fractional inspired oxygen
FRC | functional residual capacity
FVC | forced vital capacity
GERD | gastroesophageal reflux disease
GINA | Global Initiative for Asthma
GIP | Guidelines Implementation Panel (at NHLBI)
GM-CSF | granulocyte-macrophage colony-stimulating factor
HEPA | high-efficiency particulate air (a type of filter)
HFA | hydrofluoroalkane (inhaler propellant)
HMO | health maintenance organization
HPA | hypothalamic-pituitary-adrenal (usually used with "axis")
HRT | hormone replacement therapy
ICS | inhaled corticosteroid(s)
ICU | intensive care unit
IFN-γ | interferon-gamma
IgE | immunoglobulin E (and similar types, such as IgG)
IL-4, IL-12, etc. | interleukin-4, interleukin-12 (and similar)
IL-4R | interleukin-4 receptor (and similar)
INR | international normalized ratio
IVIG | intravenous immunoglobulin
IVMg | intravenous magnesium sulfate
LABA/LABAs | long-acting beta_2_-agonist(s)
LTRA | leukotriene receptor antagonist
Mab or MAb | monoclonal antibody
MDC | macrophage-derived chemokines
MDI | metered-dose inhaler
MDI/DED | metered-dose inhaler (MDI) with delivery enhancement device (DED)
MeSH | Medical Subject Headings (in MEDLINE)
MIP | macrophage inflammatory protein
NAEPP | National Asthma Education and Prevention Program
NCHS | National Center for Health Statistics
NHANES | National Health and Nutrition Examination Survey (with roman numeral)
NHIS | National Health Information Survey
NHLBI | National Heart, Lung, and Blood Institute
NIH | National Institutes of Health
NK | natural killer cells
NO or NO_2_ | nitric oxide
NSAID | nonsteroidal anti-inflammatory drug
OR | odds ratio
OSA | obstructive sleep apnea
PCO_2_ | partial pressure of carbon dioxide
PCP | primary care provider (or physician)
PD20 | 20 percent of provocative dose
PEF | peak expiratory flow
PEFR | PEF rate
PI | pulmonary index
PI_max_ | maximal pulmonary inspiration
PICU | pediatric intensive care unit
PIV | parainfluenza virus
PM10 | particulate matter _10 micrometers
RANTES | Regulated on Activation, Normal T Expressed and Secreted
RCT | randomized controlled trial
RR | relative risk
RSV | respiratory syncytial virus
RV | residual volume
SABA/SABAs | short-acting beta_2_-agonist(s) (inhaled)
SaO_2_ | oxygen saturation
SMART | Salmeterol Multicenter Asthma Research Trial
START | Inhaled Steroid Treatment as Regular Therapy in Early Asthma study
TAA | triamcinolone acetonide
TAO | troleandomycin (antibiotic)
Th1, Th2 | T cell helper 1, T cell helper 2
TLC | total lung capacity
TNF-α | tumor necrosis factor-alpha
TRUST | The Regular Use of Salbutamol Trial
USDA | U.S. Department of Agriculture
VC | vital capacity
VCD | vocal cord dysfunction
VHC | valved holding chamber
VOC | volatile organic compounds (e.g., benzene)