# Component 4: Education for a Partnership in Asthma Care

Education for a Partnership in Asthma Care