# Component 3: Pharmacologic Therapy

Pharmacologic Therapy: The Medications

Pharmacologic Therapy: Managing Asthma Long Term

Pharmacologic Therapy: Managing Exacerbations of Asthma