# Component 2: Control of Factors Contributing to Asthma Severity

Control of Factors Contributing to Asthma Severity