# Component 1: Measures of Assessment and Monitoring

Initial Assessment and Diagnosis of Asthma

Periodic Assessment and Monitoring: Essential for Asthma Management