# Overview

Introduction

Pathogenesis and Definition