# Preface

In 1991, under the auspices of the National Asthma Education and Prevention Program (NAEPP), the first Expert Panel on the Management of Asthma published Expert Panel Report: Guidelines for the Diagnosis and Management of Asthma. This landmark report redefined commonly held beliefs about asthma care, thus setting the stage for nationwide improvements in the clinical management of asthma and stimulating a variety of novel research. An enormous amount of work has been done since the release of the report to deepen our understanding of the pathogenesis of asthma and increase our knowledge about effective approaches to asthma diagnosis, monitoring, pharmacologic and environmental management, and patient education. Accordingly, the decision was made to update and revise the 1991 report to identify progress made over the last 6 years.

Expert Panel Report 2: Guidelines for the Diagnosis and Management of Asthma (EPR-2) is the culmination of more than 3 years of preparatory analysis, meetings, and writing and review cycles involving many individuals, not the least of whom were the members of the second Expert Panel. Under the able leadership of Dr. Shirley Murphy, Panel chair, the second Expert Panel diligently met its charge of producing an accurate, up-to-date source of information for clinicians on asthma diagnosis and management. Panel members conducted their work not only with skill and a depth of clinical and academic knowledge, but also with a commitment to quality and an impressive spirit of collaboration. The National Heart, Lung, and Blood Institute and the organizations that comprise the NAEPP Coordinating Committee sincerely appreciate the work of Dr. Murphy, the Expert Panel, and all others who participated in the preparation of this report.

The task before us is to explore innovative methods to broadly disseminate and encourage implementation of these updated asthma care recommendations. The first steps will be to adapt the EPR-2 into formats that meet the needs of various health professionals and then to disseminate these materials. However, these national-level efforts will have an impact on asthma care only if they occur in concert with local activities to encourage use of EPR-2 materials. Ultimately, broad change in clinical practice depends on the influence of local physicians and other health professionals who not only provide state-of-the-art care to their patients, but also communicate to their peers the importance of doing the same. We are optimistic that over the next several years, the joint efforts of the NAEPP, its Coordinating Committee member organizations, and committed professionals at the local level will result in extensive implementation of the recommendations in the EPR-2. We ask for the assistance of every reader in reaching our ultimate goal: improving asthma care and the quality of life for every patient with asthma and their families.

Publications from the National Asthma Education and Prevention Program can be ordered through the National Heart, Lung, and Blood Institute Information Center, P.O. Box 30105, Bethesda, MD 20824-0105. Publications are also available through the Internet at http://www.nhlbi.nih.gov/nhlbi/nhlbi.htm.

Claude Lenfant, M.D., Director

National Heart, Lung, and Blood Institute

Chair, National Asthma Education and

Prevention Program Coordinating Committee