# Acknowledgments

The Expert Panel acknowledges the following consultants for their review of an early draft of the report: David Evans, Ph.D.; James Fish, M.D.; Mark Liu, M.D.; Guillermo Mendoza, M.D.; Gary Rachelefsky, M.D.; Albert Sheffer, M.D.; Stanley Szefler, M.D.; and Pamela Wood, M.D.