# Pharmacologic Therapy: The Medications

Key Points
- Underdiagnosis and inappropriate therapy are major contributors to asthma morbidity and mortality.
- Goals of asthma therapy are:
  - Prevent chronic and troublesome symptoms (e.g., coughing or breathlessness in the night, in the early morning, or after exertion)
  - Maintain (near) “normal” pulmonary function
  - Maintain normal activity levels (including exercise and other physical activity)
  - Prevent recurrent exacerbations of asthma and minimize the need for emergency department visits or hospitalizations
  - Provide optimal pharmacotherapy with minimal or no adverse effects
  - Meet patients' and families' expectations of and satisfaction with asthma care
- Persistent asthma is most effectively controlled with daily anti-inflammatory therapy.
- A stepwise approach to pharmacologic therapy is recommended:
  - The amount and frequency of medication is dictated by asthma severity and directed toward suppression of increasing airway inflammation.
  - Initiate therapy at a higher level at the onset to establish prompt control and then step down.
  - Continual monitoring is essential to ensure that asthma control is achieved.
  - Step down therapy cautiously once control is achieved and sustained.
  - Step-down therapy is necessary to identify the minimum medication necessary to maintain control.
- Regular followup visits (at 1- to 6-month intervals) are essential to maintain control and consider appropriate step down in therapy.
- Therapeutic strategies should be considered in concert with clinician-patient partnership strategies; education of patients is essential for achieving optimal asthma control.
- At each step, patients should be advised to avoid or control allergens, irritants, or other factors that make the patient's asthma worse.
- Referral to an asthma specialist for consultation or comanagement is recommended if there are difficulties achieving or maintaining control of asthma or if the patient requires step 4 care. Referral may be considered for patients who require step 3 care. For patients younger than 3 years of age, referral is recommended if the patient requires step 3 or 4 care and should be considered if the patient requires step 2 care.
- New medications are available.
  - Long-acting inhaled beta_2_-agonists
    - Effective 12-hour bronchodilator
    - Adjunctive therapy to inhaled corticosteroids for maintaining control, especially helpful for nighttime symptoms
    - Not to be used to treat acute symptoms or exacerbations
  - Nedocromil
    - Similar role in therapy as cromolyn sodium, with similar safety profile
  - Leukotriene modifiers
    - Zafirlukast, leukotriene receptor antagonist, and zileuton, 5-lipoxygenase inhibitor
    - May be considered alternative daily long-term-control medications for patients with mild persistent asthma who are 12 years of age and older, but further clinical experience and study are needed to establish their roles in therapy
- Increased understanding of inhaled corticosteroids notes that:
  - Inhaled corticosteroids are the most potent inhaled anti-inflammatory agent currently available.
  - Early intervention with inhaled corticosteroids can improve asthma control and normalize lung function and may prevent irreversible airway injury.
  - Higher doses of inhaled corticosteroids may be associated with possible, but not predictable, growth retardation in children. The clinical significance of this potential systemic effect has yet to be determined.
  - Issues regarding clinical comparability and bioavailability of different preparations and different delivery systems indicate the need to adjust doses accordingly.
- Management of asthma exacerbations includes:
  - Inhaled beta_2_-agonist to provide prompt relief of airflow obstruction
  - Systemic corticosteroid, for moderate-to-severe exacerbations, to suppress and reverse airway inflammation
  - Oxygen to relieve hypoxia for moderate-to-severe exacerbations
  - Monitoring response to therapy with serial measurements of lung function

Differences from 1991 Expert Panel Report
- Medications are now categorized into two general classes: long-term-control medications used to achieve and maintain control of persistent asthma and quick-relief medications used to treat acute symptoms and exacerbations. However, the updated report continues to emphasize that the most effective medications for long-term therapy are those shown to have anti-inflammatory effects.
- New medications are available—long-acting inhaled beta_2_-agonists, nedocromil, zafirlukast, and zileuton—that have positions in therapy for long-term control and prevention of symptoms.
- There is an increased understanding of inhaled corticosteroids and their significant role in asthma therapy. An estimated clinical comparability of different inhaled corticosteroid preparations is presented.
- The stepwise approach to asthma therapy emphasizes initiating higher level therapy at the onset to establish prompt control and then stepping down.
- A new section on asthma in infants and young children incorporates recent studies on wheezing in early childhood.

Selecting the appropriate pharmacologic therapy to achieve and maintain control of asthma involves several considerations: the medications and their routes of administration, a stepwise approach to managing asthma long term as a chronic disorder, and a protocol for managing exacerbations. Each will be discussed in this component. In addition, substantial reports in the literature since publication of the 1991 Expert Panel Report have commented on the safety of regular administration of inhaled beta_2_- agonists and the potential adverse effects of inhaled corticosteroids. Because of the importance of these two classes of compounds in the treatment of asthma, it is the opinion of the Panel that special emphasis should be given to these issues. A summary is presented in this component.

The therapeutic strategies provided in this component should be considered in concert with the clinician-patient partnership strategies provided in component 4. Effective communication with, and education of, patients will increase the benefits of the therapeutic regimen.

## Key Points: the Medications

### Long-term-control medications

- Corticosteroids: Most potent and effective anti-inflammatory medication currently available. Inhaled form is used in the long-term control of asthma. Systemic corticosteroids are often used to gain prompt control of the disease when initiating long-term therapy.
- Cromolyn sodium and nedocromil: Mild-to-moderate anti-inflammatory medications. May be used as initial choice for long-term-control therapy for children. Can also be used as preventive treatment prior to exercise or unavoidable exposure to known allergens.
- Long-acting beta_2_-agonists: Long-acting bronchodilator used concomitantly with anti-inflammatory medications for long-term control of symptoms, especially nocturnal symptoms. Also prevents exercise-induced bronchospasm (EIB).
- Methylxanthines: Sustained-release theophylline is a mild-to-moderate bronchodilator used principally as adjuvant to inhaled corticosteroids for prevention of nocturnal asthma symptoms. May have mild anti-inflammatory effect.
- Leukotriene modifiers: Zafirlukast, a leukotriene receptor antagonist, or zileuton, a 5-lipoxygenase inhibitor, may be considered an alternative therapy to low doses of inhaled corticosteroids or cromolyn or nedocromil for patients ≥12 years of age with mild persistent asthma, although further clinical experience and study are needed to establish their roles in asthma therapy.

### Quick-relief medications

- Short-acting beta_2_-agonists: Therapy of choice for relief of acute symptoms and prevention of EIB.
- Anticholinergics: Ipratropium bromide may provide some additive benefit to inhaled beta_2_-agonists in severe exacerbations. May be an alternative bronchodilator for patients who do not tolerate inhaled beta_2_-agonists.
- Systemic corticosteroids: Used for moderate-to-severe exacerbations to speed recovery and prevent recurrence of exacerbations.

## Overview of the Medications

Pharmacologic therapy is used to prevent and control asthma symptoms, reduce the frequency and severity of asthma exacerbations, and reverse airflow obstruction. Recommendations in this component reflect the scientific concept that asthma is a chronic disorder with recurrent episodes of airflow limitation, mucus production, and cough. Asthma medications are thus categorized into two general classes: long-term-control medications taken daily on a long-term basis to achieve and maintain control of persistent asthma (these medications are also known as long-term preventive, controller, or maintenance medications) and quick-relief medications taken to provide prompt reversal of acute airflow obstruction and relief of accompanying bronchoconstriction (these medications are also known as reliever or acute rescue medications). Patients with persistent asthma require both classes of medication. Tables 6-1 and 6-2 present summaries of the indications, mechanisms, potential adverse effects, and therapeutic issues for currently available long-term-control and quick-relief medications.

Table 6-1 Long-Term-Control Medications

Name/Products | Indications/Mechanisms | Potential Adverse Effects | Therapeutic Issues
Corticosteroids (Glucocorticoids) | Indications
| Long-term prevention of symptoms; suppression, control, and reversal of inflammation. | Cough, dysphonia, oral thrush (candidiasis). | Spacer/holding chamber devices and mouth washing after inhalation decrease local side effects and systemic absorption.
Inhaled:
Beclomethasone dipropionate, Budesonide, Flunisolide, Fluticasone propionate, Triamcinolone acetonide | Reduce need for oral cortkosteroid. | In high doses (see table 7-2), systemic effects may occur, although studies are not conclusive, and clinical significance of these effects has not been established (e.g., adrenal suppression, osteoporosis, growth suppression, and skin thinning and easy bruising) (Barnes and Pedersen 1993; Kamada et al. 1996). | Preparations are not absolutely interchangeable on a meg or per puff basis (see box 7-1 for estimated clinical comparability). New delivery devices may provide greater delivery to airways, which may affect dose.
| Mechanisms
| Anti-inflammatory. Block late reaction to allergen and reduce airway hyperresponsiveness. Inhibit cytokine production, adhesion protein activation, and inflammatory cell migration and activation. | | The risks of uncontrolled asthma should be weighed against the limited risks of inhaled corticosteroids. The potential but small risk of adverse events is well balanced by their efficacy. (See text.)
| Reverse beta_2_-receptor down-regulation. Inhibit microvascular leakage. | | Dexamethasone is not included because it is highly absorbed and has long-term suppressive side effects.
Systemic: | Indications
Methylprednisolone, Prednisolone, Prednisone | For short-term (3–10 days) “burst”: to gain prompt control of inadequately controlled persistent asthma. | Short-term use: reversible, abnormalities in glucose metabolism, increased appetite, fluid retention, weight gain, mood alteration, hypertension, peptic ulcer, and rarely aseptic necrosis of femur. | Use at lowest effective dose. For long-term use, alternate-day a.m. dosing produces least toxicity. If daily doses are required, one study shows improved efficacy with no increase in adrenal suppression when administered at 3 p.m. rather than in the morning (Beam et al. 1992).
| For long-term prevention of symptoms in severe persistent asthma: suppression, control, and reversal of inflammation. | Long-term use: adrenal axis suppression, growth suppression, dermal thinning, hypertension, diabetes, Cushing's syndrome, cataracts, muscle weakness, and — in rare instances — impaired immune function.
| Mechanisms
| Same as inhaled. | Consideration should be given to coexisting conditions that could be worsened by systemic corticosteroids, such as herpes virus infections, varicella, tuberculosis, hypertension, peptic ulcer, and Strongyloides.
Cromolyn Sodium and Nedocromil | Indications
| Long-term prevention of symptoms; may modify inflammation. | 15 to 20 percent of patients complain of an unpleasant taste from nedocromil. | Therapeutic response to cro-molyn and nedocromil often occurs within 2 weeks, but a 4- to 6-week trial may be needed to determine maximum benefit.
| Preventive treatment prior to exposure to exercise or known allergen.
| Mechanisms
| Anti-inflammatory. Block early and late reaction to allergen. Interfere with chloride channel function. Stabilize mast cell membranes and inhibit activation and release of mediators from eosinophils and epithelial cells. | | Dose of cromolyn MDI (1 mg/puff) may be inadequate to affect airway hyperresponsiveness. Nebulizer delivery (20 mg/ampule) may be preferred for some patients
| Inhibit acute response to exercise, cold dry air, and SO_2_. | | Safety is the primary advantage of these agents.
Long-Acting Beta_2_-Agonists | Indications
| Long-term prevention of symptoms, especially nocturnal symptoms, added to anti-inflammatory therapy | Tachycardia, skeletal muscle tremor, hypokalemia, prolongation of QT_C_ interval in overdose. | Not to be used to treat acute symptoms or exacerbations.
Inhaled:
Salmeterol | Prevention of exercise-induced bronchospasm. | A diminished bronchoprotec-tive effect may occur within 1 week of chronic therapy. Clinical significance has not been established. | Clinical significance of potentially developing tolerance is uncertain because studies show symptom control and bronchodilation are maintained.
| Not to be used to treat acute symptoms or exacerbations. | | Should not be used in place of anti-inflammatory therapy.
| Mechanisms
| Bronchodilation. Smooth muscle relaxation following adenylate cyclase activation and increase in cyclic AMP producing functional antagonism of bronchoconstriction. | See text for additional discussion. | May provide more effective symptom control when added to standard doses of inhaled corticosteroid compared to increasing the corticosteroid dosage.
| In vitro, inhibit mast cell mediator release, decrease vascular permeability, and increase mucociliary clearance.
| Compared to short-acting inhaled beta_2_-agonist, sakne-terol (but not formoterol) has slower onset of action (15 to 30 minutes) but longer duration (> 12 hours).
Oral:
Albuterol, sustained-release | | | Inhaled long-acting beta_2_-agonists are preferred because they are longer acting and have fewer side effects than oral sustained-release agents.
Methylxanthines | Indications
Theophylline, sustained-release tablets and capsules | Long-term control and prevention of symptoms, especially nocturnal symptoms. | Dose-related acute toxicities include tachycardia, nausea and vomiting, tachyarrhythmias (SVT), central nervous system stimulation, headache, seizures, hematemesis, hyperglycemia, and hypokalemia. | Maintain steady-state serum concentrations between 5 and 15 mcg/mL. Routine serum concentration monitoring is essential due to significant toxicities, narrow therapeutic range, and individual differences in metabolic clearance. Absorption and metabolism may be affected by numerous factors (see table 7-1), which can produce significant changes in steady-state serum theo-phylline concentrations.
| Mechanisms
| Bronchodilation. Smooth muscle relaxation from phospho-diesterase inhibition and possibly adenosine antagonism | Adverse effects at usual therapeutic doses include insomnia, gastric upset, aggravation of ulcer or reflux, increase in hyperactivity in some children, difficulty in urination in elderly males with prostatism. | Not generally recommended for exacerbations. There is minimal evidence for added benefit to optimal doses of inhaled beta_2_-agonists. Serum concentration monitoring is mandatory.
| May affect eosinophilic infiltration into bronchial mucosa as well as decrease T-lymphocyte numbers in epithelium.
| Increases diaphragm contractility and mucociliary clearance.
Leukotriene Modifiers
Zafirlukast tablets | Indications
| Long-term control and prevention of symptoms in mild persistent asthma for patients ≥12 years of age. | No specific adverse effects to date. As with any new drug, there is possibility of rare hypersensitivity or idiosyncratic reactions that cannot usually be detected in initial premarkedng trials. One reported case of reversible hepatitis and hyperbilirubinemia; high concentrations may develop in patients with liver impairment. | Administration with meals decreases bioavailability; take at least 1 hour before or 2 hours after meals.
| Mechanisms
| Leukotriene receptor antagonist; selective competitive inhibitor of LTD4 and LTE4 receptors. | | Inhibits the metabolism of warfarin and increases pro-thrombin time; it is a competitive inhibitor of the CYP2C9 hepatic microsomal isozymes. (It has not affected elimination of terfenadine, theophylline, or ethinyl estra-diol drugs metabolized by the CYP3A4 isozymes.)
Zileuton tablets | Indications
| Long-term control and prevention of symptoms in mild persistent asthma for patients ≥12 years of age. | Elevation of liver enzymes has been reported. Limited case reports of reversible hepatitis and hyperbilirubinemia. | Zileuton is microsomal CYP3A4 enzyme inhibitor that can inhibit the metabolism of terfenadine, warfarin, and theophylline. Doses of these drugs should be monitored accordingly.
| Mechanisms
| 5-lipoxygenase inhibitor. | | Monitor hepatic enzymes (ALT).

Table 6-2 Quick-Relief Medications

Name/Products | Indications/Mechanisms | Potential Adverse Effects | Therapeutic Issues
Short-Acting Inhaled Beta_2_-Agonists | Indications
Albuterol, Bitolterol, Pirbuterol, Terbutaline | Relief of acute symptoms; quick-relief medication. | Tachycardia, skeletal muscle tremor, hypokalemia, increased lactic acid, headache, hyperglycemia. Inhaled route, in general, causes few systemic adverse effects. Patients with preexisting cardiovascular disease, especially the elderly, may have adverse cardiovascular reactions with inhaled therapy. | Drugs of choice for acute bronchospasm. Inhaled route has faster onset, fewer adverse effects, and is more effective than systemic routes. The less beta_2_-selective agents (isoproterenol, metaproterenol, isoetharine, and epinephrine) are not recommended due to their potential for excessive cardiac stimulation, especially in high doses. Albuterol liquid is not recommended.
| Preventive treatment prior to exercise for exercise-induced bronchospasm.
| Mechanisms
| Bronchodilation. Smooth muscle relaxation following adenylate cyclase activation and increase in cyclic AMP producing functional antagonism of bronchoconstriction. | | For patients with mild intermittent asthma, regularly scheduled daily use neither harms nor benefits asthma control (Drazen et al. 1996). Regularly scheduled daily use is not generally recommended.
| | | Increasing use or lack of expected effect indicates inadequate asthma control. > 1 canister a month (e.g., albuterol-200 puffs per canister) may indicate overreliance on this drug; ≥2 canisters in 1 month poses additional adverse risks.
| | | For patients frequently using beta_2_-agonist, anti-inflammatory medication should be initiated or intensified.
Anticholinergics | Indications
Ipratropium bromide | Relief of acute bronchospasm (see Therapeutic Issues column). | Drying of mouth and respiratory secretions, increased wheezing in some individuals, blurred vision if sprayed in eyes. | Reverses only cholinergically mediated bronchospasm; does not modify reaction to antigen. Does not block exercise-induced bronchospasm.
| Mechanisms
| Bronchodilation. Competitive inhibition of muscarinic cholinergic receptors. | | May provide additive effects to beta_2_-agonist but has slower onset of action.
| Reduces intrinsic vagal tone to the airways. May block reflex bronchoconstriction secondary to irritants or to reflux esophagitis. | | Is an alternative for patients with intolerance to beta_2_-agonists.
| May decrease mucus gland secretion. | | Treatment of choice for bronchospasm due to beta-blocker medication.
Corticosteroids | Indications
Systemic: | For moderate-to-severe exacerbations to prevent progression of exacerbation, reverse inflammation, speed recovery, and reduce rate of relapse. | Short-term use: reversible abnormalities in glucose metabolism, increased appetite, fluid retention, weight gain, mood alteration, hypertension, peptic ulcer, and rarely aseptic necrosis of femur. | Short-term therapy should continue until patient achieves 80% PEF personal best or symptoms resolve. This usually requires 3 to 10 days but may require longer.
Methylprednisolone, Prednisolone, Prednisone
| Mechanisms
| Anti-inflammatory. See table 6-1. | Consideration should be given to coexisting conditions that could be worsened by systemic corticosteroids, such as herpes virus infections, varicella, tuberculosis, hypertension, peptic ulcer, and Strongyloides. | There is no evidence that tapering the dose following improvement prevents relapse.

### Long-Term-Control Medications

Long-term-control medications are taken daily on a long-term basis to achieve and maintain control of persistent asthma. They include anti-inflammatory agents, long-acting bronchodilators, and leukotriene modifiers. Because eosinophilic inflammation is a constant feature of the mucosa of the airways in asthma, the most effective long-term-control medications are those that attenuate inflammation (Haahtela et al. 1991; Kerrebijn et al. 1987; van Essen-Zandvliet et al. 1992). The Expert Panel defines anti-inflammatory medications as those that cause a reduction in the markers of airway inflammation in airway tissue or airway secretions (e.g., eosinophils, mast cells, activated lymphocytes, macrophages, and cytokines; or eosinophilic cationic protein and tryptase; or extravascular leakage of albumin, fibrinogen, or other vascular protein) and thus decrease the intensity of airway hyperresponsiveness. Because many factors contribute to the inflammatory response in asthma, many drugs may be considered anti-inflammatory. It is not yet established, however, which anti-inflammatory actions are responsible for therapeutic effects, such as reduction in symptoms, improvement in expiratory flow, reduction in airway hyperresponsiveness, prevention of exacerbations, or prevention of airway wall remodeling.

#### Corticosteroids

Corticosteroids are the most potent and consistently effective long-term-control medication for asthma. Their broad action on the inflammatory process may account for their efficacy as preventive therapy. Their clinical effects include reduction in severity of symptoms, improvement in peak expiratory flow and spirometry, diminished airway hyperresponsiveness, prevention of exacerbations, and possibly the prevention of airway wall remodeling (Barnes et al. 1993; Jeffery et al. 1992; Dahl et al. 1993; Fabbri et al. 1993; Gustafsson et al. 1993; Haahtela et al. 1991; Kamada et al. 1996; Rafferty et al. 1985; van Essen-Zandvliet et al. 1992). Which of these clinical effects depend on specific anti-inflammatory actions of corticosteroids is not yet clear. Corticosteroids suppress the generation of cytokines, recruitment of airway eosinophils, and release of inflammatory mediators. These anti-inflammatory actions of corticosteroids have been noted in clinical trials and analyses of airway histology (Busse 1993; Booth et al. 1995; Laitinen et al. 1992; Djukanovic et al. 1992; Duddridge et al. 1993; Laitinen et al. 1991; Levy et al. 1995; McGill et al. 1995).

Dosages for inhaled corticosteroids vary depending upon the specific product and delivery devices (see table 7-2). For many patients, a twice-a-day dosing schedule maintains control of asthma; even high doses of some preparations are effective when given twice a day (Noonan et al. 1995). Some studies show that once-daily dosing is effective in mild persistent asthma (Jones et al. 1994; Pincus et al. 1995).

#### Cromolyn Sodium and Nedocromil

Although cromolyn and nedocromil have distinct properties (Clark 1993), they have similar anti-inflammatory actions. Their mechanism appears to involve the blockade of chloride channels (Alton and Norris 1996), and they modulate mast cell mediator release and eosinophil recruitment (Eady 1986). They also inhibit the early and late asthmatic response to allergen challenge and exercise-induced bronchospasm (EIB) (Novembre et al. 1994; Alton and Norris 1996; Thompson 1989; Gonzalez and Brogden 1987).

The two compounds are equally effective against allergen challenge (Gonzalez and Brogden 1987), although nedocromil appears to be more potent than cromolyn in inhibiting bronchospasm provoked by exercise (Novembre et al. 1995; deBenedictis et al. 1995), by cold dry air (Juniper et al. 1987), and by bradykinin aerosol (Dixon and Barnes 1989).

Both compounds have been shown to reduce asthma symptoms, improve morning peak flow, and reduce need for quick-relief beta_2_-agonists (Lal et al. 1993; Schwartz et al. 1996). Two large clinical trials comparing nedocromil MDI 4 mg qid to cromolyn MDI 2 mg qid demonstrated that they are generally comparable in mild allergic patients and that nedocromil was more effective than cromolyn in nonallergic patients using inhaled corticosteroids. Furthermore, nedocromil may have a modest effect in helping reduce the dose requirements for inhaled corticosteroids (Lal et al. 1993; O'Hickey and Rees 1994; Svendsen and Jorgensen 1991), although some studies did not demonstrate this effect (Wong et al. 1993).

Dosing recommendations for both drugs are for administration four times a day, although nedocromil has been shown to be clinically effective with twice-daily dosing (Creticos et al. 1995).

The clinical response to cromolyn and nedocromil is less predictable than the response to inhaled corticosteroids. Both compounds have a strong safety profile.

#### Long-Acting Beta_2_-Agonists (Beta-Adrenergic Agonists)

The principal action of beta_2_-agonists is to relax airway smooth muscle by stimulating beta_2_-receptors, which increases cyclic AMP and produces functional antagonism to bronchoconstriction. Long-acting inhaled beta_2_-agonists have a duration of bronchodilation of at least 12 hours after a single dose (Becker and Simons 1989; D'Alonzo et al. 1994). This class of medication is not to be used for exacerbations. Rather, it is used as an adjunct to anti-inflammatory therapy for providing long-term control of symptoms, especially nocturnal symptoms (Yates et al. 1995) and to prevent exercise-induced bronchospasm. The use and safety of beta_2_-agonists are discussed on page 67, Special Issues Regarding Safety.

#### Methylxanthines

Theophylline, the principally used methylxanthine, provides mild-to-moderate bronchodilation in asthma. Although its mechanism of action has yet to be established (Weinberger and Hendeles 1996; Hendeles et al. 1995), recent evidence suggests that low serum concentrations of theophylline are mildly anti-inflammatory (Sullivan et al. 1994; Kidney et al. 1995; Pauwels 1989). Sustained-release theophylline's main use is as adjuvant therapy, and it is particularly effective for controlling nocturnal asthma symptoms. Sustained-release theophylline may be considered as an alternative, but not preferred, long-term preventive therapy when issues arise concerning cost or adherence to regimens using inhaled medication. Monitoring serum concentration levels is essential to ensure that therapeutic, but not toxic, doses are achieved.

#### Leukotriene Modifiers

Leukotrienes are potent biochemical mediators released from mast cells, eosinophils, and basophils that contract airway smooth muscle, increase vascular permeability, increase mucus secretions, and attract and activate inflammatory cells in the airways of patients with asthma (Henderson 1994). Two leukotriene modifiers—zafirlukast and zileuton—have recently become available as oral tablets for the treatment of asthma.

From the information currently available, it appears that leukotriene modifiers improve lung function (Gaddy et al. 1992) and diminish symptoms and the need for short-acting inhaled beta_2_-agonists. The majority of trials have been conducted in mildto-moderate asthma, and the improvements noted have been modest. Leukotriene modifiers may be considered an alternative to low-dose inhaled corticosteroid therapy for patients with mild persistent asthma, although increased clinical experience and further study in a wide range of patients are needed to determine those patients most likely to benefit from leukotriene modifiers and to establish a more specific role for leukotriene modifiers in asthma therapy.

Zafirlukast, a leukotriene receptor antagonist, has been demonstrated to attenuate the late response to inhaled allergen and post-allergen induced bronchial responsiveness (Dahlen et al. 1994; Taylor et al. 1991). Studies comparing zafirlukast to placebo in patients with mild-to-moderate asthma demonstrated that patients treated with zafirlukast experienced modest improvement in FEV_1_ (mean improvement of 11 percent above placebo), improved symptom scores, and reduced albuterol use (average decline of 1 puff/day) (Spector et al. 1994). In a small study of healthy males, 60 mg a day of zafirlukast caused a significant increase in the half-life of warfarin. Consequently, for those individuals receiving zafirlukast and warfarin, it will be necessary to closely monitor prothrombin times and adjust doses of warfarin accordingly.

Zileuton, a 5-lipoxygenase inhibitor, has been demonstrated to provide immediate and sustained improvements in FEV_1_ (mean increase of 15 percent above placebo) in placebo-controlled trials in patients with mild-to-moderate asthma (Israel et al. 1993, 1996). Compared to placebo, the patients with moderate asthma treated with zileuton experienced significantly fewer exacerbations requiring oral corticosteroids (Israel et al. 1996), thus suggesting anti-inflammatory action. Finally, zileuton is capable of attenuating bronchoconstriction from exercise (Meltzer et al. 1996) and from aspirin in aspirin-sensitive individuals (Israel et al. 1993). Because liver toxicity has been found in some subjects receiving zileuton, it is recommended that hepatic enzymes (ALT) be monitored in patients who take this medication. Zileuton is a microsomal CYP3A4 enzyme inhibitor that can inhibit the metabolism of terfenadine, warfarin, and theophylline. Doses of these drugs should be monitored accordingly.

### Quick-Relief Medications

Quick-relief medications are used to provide prompt relief of bronchoconstriction and its accompanying acute symptoms such as cough, chest tightness, and wheezing. They include short-acting beta_2_-agonists and anticholinergics. Although the onset of action is slow (>4 hours), systemic corticosteroids are important in the treatment of moderate-to-severe exacerbations because they prevent progression of the exacerbation, speed recovery, and prevent early relapses.

#### Short-Acting Beta_2_-Agonists

Short-acting beta_2_-agonists relax airway smooth muscle and cause a prompt (within 30 minutes) increase in airflow. Inhaled short-acting beta_2_-agonists are the drug of choice for treating acute asthma symptoms and exacerbations and for preventing EIB. Concerns about the safety of short-acting beta_2_-agonists are discussed in another section of this component (see page 67, Special Issues Regarding Safety).

#### Anticholinergics

Cholinergic innervation is an important factor in the regulation of airway smooth muscle tone. Ipratropium bromide is a quaternary derivative of atropine that does not have atropine's side effects. Ipratropium bromide may provide some additive benefit with inhaled beta_2_-agonists in severe asthma exacerbations. Its effectiveness in long-term management of asthma has not been demonstrated (Kerstjens et al. 1992; Gross 1988; Storms et al. 1986).

#### Systemic Corticosteroids

Systemic corticosteroids can speed resolution of airflow obstruction and reduce the rate of relapse (Fanta et al. 1983; Rowe et al. 1992; Scarfone et al. 1993; Connett et al. 1994; Chapman et al. 1991).

### Medications To Reduce Oral Systemic Corticosteroid Dependence

#### Troleandomycin, Cyclosporine, Methotrexate, Gold, Intravenous Immunoglobulin, Dapsone, and Hydroxychloroquine

These regimens to reduce oral systemic corticosteroid dependence should be used only in selected patients who are under the supervision of an asthma specialist. Although some of the compounds have corticosteroid-sparing effects, their use in asthma remains complicated because of highly variable effects, potential toxicity, and limited clinical experience (Bernstein et al. 1996; Jarjour et al. 1996; Mullarkey et al. 1988; Shiner et al. 1990; Erzurum et al. 1991; Muranaka et al. 1978; Klaustermeyer et al. 1987; Kamada et al. 1993; Nelson et al. 1993; Alexander et al. 1992; Mazer and Gelfand 1991). Colchicine is not considered effective in reducing need for oral systemic or high doses of inhaled corticosteroids (Newman et al. 1997).

### Complementary Alternative Medicine

Alternative healing methods are not substitutes for recommended pharmacologic therapy. Although alternative healing methods may be popular with selected patients and of some interest to investigators, their scientific basis has not been established.

The most widely known complementary alternative medicine methods are acupuncture, homeopathy, herbal medicine, and Ayurvedic medicine (which includes transcendental meditation, herbs, and yoga). A review of multiple trials on the use of acupuncture in asthma concluded that the trials lacked quality and that the effectiveness of acupuncture in treating asthma has not been established (Kleijnen et al. 1991). One trial, however, demonstrated benefit in EIB (Fung et al. 1986). Homeopathy, based on the “law of similars” and the use of infinitesimally small doses, is as yet unproven for asthma (Reilly et al. 1986); some homeopathic remedies may contain potent unidentified pharmacologic agents (Morice 1986). No controlled clinical trials have been reported on herbal medicines, and the claims of effectiveness of western plant derivatives for asthma remain unsubstantiated (Dorsch and Wagner 1991; Ziment and Stein 1993). Because complementary alternative medicine is reported to be used by as much as one-third of the U.S. population (Eisenberg et al. 1993), it may be important to inquire about all the medications a patient uses and advise the patient accordingly (see component 4).

## Route of Administration

Medications for asthma can be administered either by inhaled or systemic routes. Systemic routes are oral (ingested) or parenteral (subcutaneous, intramuscular, or intravenous). The major advantages of delivering drugs directly into the lungs via inhalation are that higher concentrations can be delivered more effectively to the airways and that systemic side effects are avoided or minimized (Newhouse and Dolovich 1986). Furthermore, the onset of action of inhaled bronchodilators is substantially shorter than that of oral bronchodilators.

Inhaled medications, or aerosols, are available in a variety of devices that differ in technique required and quantity of drug delivered to the lung. See table 6-3 for a summary of issues to consider for different devices. Whatever device is selected, patients should be instructed in its use and their technique checked regularly.

Table 6-3 Aerosol Delivery Devices

Device/Drugs | Population | Optimal Technique* | Therapeutic Issues
Metered-dose inhaler (MDI) | >5 years | Actuation during a slow (30 L/min or 3–5 seconds) deep inhalation, followed by 10-second breath-holding. | Slow inhalation may be difficult. Difficulty with coordination of actuation and inhalation, particularly in young children and elderly. Patients may incorrectly stop inhalation at actuation. Deposition of 80 percent of actuated dose in oropharynx. Mouth washing is effective in reducing systemic absorption (Selroos and Halme 1991).
Beta_2_-agonists, Corticosteroids, Cromolyn sodium and nedocromil, Anticholinergics
| | Under laboratory conditions, open-mouth technique (holding MDI 2 inches away from open mouth) enhances delivery to the lung. However, it has not consistently been shown to enhance clinical benefit compared to closed-mouth technique (closing lips around MDI mouthpiece).
Breath-actuated MDI | >5 years | Slow (30 L/min or 3–5 seconds) inhalation followed by 10-second breath-holding. | Indicated for patients unable to coordinate inhalation and actuation. May be particularly useful in elderly (Newman et al. 1991). Slow inhalation may be difficult and patients may incorrectly stop inhalation at actuation. Requires more rapid inspiration to activate than is optimal for deposition. Cannot be used with currently available spacer/holding chamber devices.
Beta_2_-agonists
Dry powder inhaler (DPI) | | Rapid (60 L/min or 1–2 seconds), deep inhalation. Minimally effective inspiratory flow is device dependent. | Dose lost if patient exhales through device. Delivery may be 2≥MDI depending on device and technique. Can be used in children 4 years old, but effects are more consistent with children >5 (Pedersen et al. 1990; Goren et al. 1994; Kemp et al. 1989; Kesten et al. 1994). Most appear to have similar delivery efficiency as MDI either with or without spacer/holding chamber, but some may have delivery >MDI (Thorsson et al. 1994; Agertoft and Pedersen 1993; Kemp et al. 1989; Melchor et al. 1993; Vidgren et al. 1983). Mouth washing is effective in reducing systemic absorption (Selroos and Halme 1991).
Beta_2_-agonists, Corticosteroids
Spacer/holding chamber | >4 years | Slow (30 L/min or 3–5 seconds) inhalation or tidal breathing immediately following actuation. | Easier to use than MDI alone. With a face mask, enables MDI to be used with small children (Everard et al. 1992; Connett et al. 1993). Simple tubes do not obviate coordinating actuation and inhalation. Bulky. Output may be reduced in some devices after cleaning. The larger volume spacers/holding chambers (>600 cc) may increase lung delivery over MDI alone in patients with poor MDI technique. The effect of a spacer/holding chamber on output from an MDI is dependent on both MDI and spacer type; thus data from one combination should not be extrapolated to all others (Ahrens et al. 1995; Kim etal. 1987).
| ≤4 years with face mask | Actuation only once into spacer/holding chamber per inhalation (O'Callaghan et al. 1994). If face mask is used, allow 3–5 inhalations per actuation (Everard et al. 1992). | Spacers/holding chambers decrease oropharyngeal deposition and will reduce potential system absorption of inhaled corticosteroid preparations that have higher oral bioavailability (Newman et al. 1984; Brown et al. 1990; Lipworth 1995; Selroos and Halme 1991). Spacers/ holding chambers are recommended for all patients on medium-to-high doses of inhaled corticosteroids.
| | | May be as effective as nebulizer in delivering high doses of beta_2_-agonists during severe exacerbations.
Nebulizer | ≤2 years | Slow tidal breathing with occasional deep breaths. | Less dependent on patient coordination or cooperation.
Beta_2_-agonists, Cromolyn, Anticholinergics, Corticosteroids
| Patients of any age who cannot use MDI with spacer/ holding chamber or spacer and face mask (e.g., during exacerbations) | Tightly fitting face mask for those unable to use mouthpiece. | Delivery method of choice for cromolyn in children and for high-dose beta_2_-agonists and anticholinergics in moderate-to-severe exacerbations in all patients.
| | | Expensive; time consuming; bulky; output is device dependent; and there are significant internebulizer and intranebulizer output variances.

* See figure 9-1 for description of MDI and DPI techniques.

Sources: Agertoft and Pedersen 1993; Ahrens et al. 1995; Brown et al. 1990; Connett et al. 1993; Higgins et al. 1987; Crompton and Duncan 1989; Everard et al. 1992; Fuglsang and Pedersen 1986; Goren et al. 1994; Kemp et al. 1989; Kesten et al. 1994; Kim et al. 1987; Lipworth 1995; Melchor et al. 1993; Newman et al. 1981, 1984, 1991; O'Callaghan et al. 1994; Pedersen et al. 1990; Pedersen and Mortensen 1990; Prahl and Jensen 1987; Rossing et al. 1980; Ruggins et al. 1993; Schecker et al. 1993; Selroos and Halme 1991; Selroos et al. 1995; Thorsson et al. 1994; Vidgren et al. 1983.

Most inhaled medications currently used for asthma are available as metered-dose inhalers (MDIs). Historically, MDI technology has utilized chlorofluorocarbons (CFCs) as propellants. CFCs usually constitute 95 percent or more of the formulation emitted from an MDI; CFCs are metabolically stable and even the portion of an actuation that is systemically absorbed is quickly excreted unchanged via exhalation. However, CFCs have been found to deplete stratospheric ozone and have been banned internationally. Although a temporary medical exemption has been granted, it is expected that CFC-propelled MDIs will eventually be phased out completely. Alternatives include MDIs with other propellants (nonchlorinated propellants such as hydrofluoroalkane [HFA] 134a do not have ozone-depleting properties), multidose dry powder inhalers, and other hand-held devices with convenience and delivery characteristics similar to current MDIs. An MDI for albuterol with HFA 134a has been approved for use; additional non-CFC products and delivery systems are expected in the future. The Food and Drug Administration approval process requires that the replacement products demonstrate comparability to the corresponding CFC products so that clinicians and patients can anticipate similar effectiveness and safety with the new products. During the phaseout of CFC products, clinicians will need to be informed of the alternatives and assist their patients in the transition to non-CFC products (see component 4).

## Special Issues Regarding Safety

### Short-Acting Inhaled Beta_2_-Agonists

Key Points: Short-Acting Inhaled Beta_2_-Agonists

- Short-acting beta_2_-agonists are the most effective medication for relieving acute bronchospasm.
- Increasing use of short-acting beta_2_-agonists or the use of more than one canister in 1 month indicates inadequate control of asthma and the need for initiating or intensifying anti-inflammatory therapy.
- Regularly scheduled, daily use of short-acting beta_2_-agonists is generally not recommended.

Short-acting inhaled beta_2_-agonists (e.g., albuterol) are the medications of choice for treating exacerbations of asthma and for preventing EIB. Prior to 1990, many clinicians prescribed short-acting beta_2_-agonists on a regularly scheduled basis in the belief that this treatment regimen improved overall asthma symptom control. Some recent reports, however, have modified these beliefs. For example, in moderate asthma, regular use of a potent inhaled beta_2_-agonist (fenoterol) produced a significant diminution in asthma control and objective measurements of pulmonary function (Sears et al. 1990). In mild asthma, regularly scheduled use of albuterol compared to use on an as-needed basis only resulted in no significant differences in a variety of outcome indices. Although regularly scheduled use of beta_2_-agonists in mild asthma produced no harmful effects in a 4-month period, it also produced no demonstrable benefits (Drazen et al. 1996). Similar findings were noted in studies with moderate asthma (D'Alonzo et al. 1994; Pearlman et al. 1992). Based on these and other observations (Cockcroft et al. 1993; van Schayck et al. 1991; O'Connor et al. 1992; Mullen et al. 1993; Ernst et al. 1993; Suissa et al. 1994), the regularly scheduled, daily use of short-acting beta_2_-agonists is not generally recommended.

The frequency of beta_2_-agonist use can be clinically useful as a barometer of disease activity because increasing use of beta_2_-agonists has been associated with increased risk for death or near death in patients with asthma (Spitzer et al. 1992). The use of more than one beta_2_-agonist canister (e.g., albuterol, 200 puffs per canister) predominantly for quick-relief treatment during a 1-month period most likely indicates overreliance on this drug and suggests inadequate asthma control (Spitzer et al. 1992).

### Long-Acting Inhaled Beta_2_-Agonists

Key Points: Long-Acting Inhaled Beta_2_-Agonists

- Long-acting beta_2_-agonists (salmeterol) can be beneficial to patients when added to inhaled corticosteroid therapy, especially to control nighttime symptoms (Greening et al. 1994; Woolcock et al. 1996). Daily use of long-acting beta_2_-agonists should generally not exceed 84 mcg (salmeterol; four puffs).
- Salmeterol is not to be used for treatment of acute symptoms or exacerbations.
- Patient education regarding correct use of salmeterol is critical.
- Patients should be instructed not to stop anti-inflammatory therapy while taking salmeterol even though their symptoms may significantly improve.

Long-acting beta_2_-agonists have several beneficial clinical properties. They attenuate EIB for longer time periods than do short-acting beta_2_-agonists (Green and Price 1992; Henriksen et al. 1992) and improve nocturnal asthma symptoms (Fitzpatrick et al. 1990; Maesen et al. 1990). Recent studies suggest that for patients with inadequate symptom control who are receiving low-to-medium doses of inhaled corticosteroids, it may be more beneficial to add salmeterol than to increase the dose of inhaled corticosteroids (Greening et al. 1994; Woolcock et al. 1996). Furthermore, in one study, salmeterol resulted in statistically significant increases in overall quality of life (Juniper et al. 1995) although the clinical significance of the reported differences is not certain.

Several studies report that patients do not appear to develop a tolerance to the bronchodilator action of salmeterol even after months of regular treatment (D'Alonzo et al. 1994; Lotvall et al. 1992; Pearlman et al. 1992; Ullman et al. 1990). In contrast, in bronchoprovocation studies following chronic administration of either short-acting or long-acting beta_2_-agonists, a decrease was demonstrated in the bronchoprotective effect against exercise (Ramage et al. 1994), allergen (Cockcroft et al. 1993, 1995; Bhagat et al. 1996), and methacholine (Bhagat et al. 1996; Cheung et al. 1992). However, the bronchoprotective effect over time, although diminished, was still significantly greater than placebo. Thus, the clinical importance of the reported decrease in bronchoprotective effect remains uncertain (McFadden 1995).

Following the introduction of salmeterol into clinical practice, case reports of sudden severe attacks of asthma (Clark et al. 1993) raised concerns that in certain asthma patients, under certain conditions, the use of salmeterol may cause a sudden worsening of symptoms and possibly death. A recent randomized study in England compared more than 16,000 patients who received regular salmeterol for a 16-week period with more than 8,000 patients receiving regular (qid) albuterol therapy. The study found more deaths in the salmeterol group; however, the differences did not reach statistical significance (Castle et al. 1993). Nor did a prescription-event monitoring survey demonstrate a statistically significant difference in deaths (Mann et al. 1996). Several large studies have demonstrated that, overall, patients taking salmeterol do not experience an increase in the frequency of exacerbations (Britton et al. 1992; Lundback et al. 1993; Greening et al. 1994; Pearlman et al. 1992; Woolcock et al. 1996). There are ongoing longitudinal studies to determine if there might be risk for special populations. The potential for patients to incorrectly use salmeterol as a quick-relief medication warrants special attention by the clinician and appropriate patient education. Based on current information, long-acting inhaled beta_2_-agonists should be used only in conjunction with anti-inflammatory medication. When added to inhaled corticosteroids, long-acting inhaled beta_2_-agonists are helpful long-term-control therapy.

### Inhaled Corticosteroids

Key Points: Inhaled Corticosteroids

- Inhaled corticosteroids are the most effective long-term therapy available for mild, moderate, or severe persistent asthma; in general, inhaled corticosteroids are well tolerated and safe at the recommended dosages.
- The potential but small risk of adverse events from the use of inhaled corticosteroids is well balanced by their efficacy.
- To reduce the potential for adverse effects, the following measures are recommended:
  - Administer inhaled corticosteroids with spacers/holding chambers.
  - Advise patients to rinse their mouths (rinse and spit) following inhalation.
  - Use the lowest possible dose of inhaled corticosteroid to maintain control.
  - To maintain control of asthma (especially for nocturnal symptoms), consider adding a long-acting inhaled beta_2_-agonist to a low-to-medium dose of inhaled corticosteroid rather than using a higher dose of inhaled corticosteroid.
  - For children, monitor growth (see box on page 72).
  - For postmenopausal women, consider supplements of calcium (1,000 to 1,500 mg per day) and vitamin D (400 units a day). Estrogen replacement therapy, where appropriate, may be considered for patients on doses that exceed 1,000 mcg of inhaled corticosteroid a day.

Inhaled corticosteroids are the most effective long-term therapy available for patients with persistent asthma. In general, inhaled corticosteroids are well tolerated and safe at the recommended dosages (Barnes 1995; van Essen-Zandvliet et al. 1992; Tinkelman et al. 1993). Systemic effects have been identified, particularly at high doses (see table 7-2 for a definition of high-, medium-, and low-dose inhaled corticosteroids), but their clinical significance remains unclear. Furthermore, there may be interindividual variations in dose-response effects, and thus some patients may experience effects at lower doses. (See Key Points above for a summary of recommendations to minimize the potential for adverse effects.) In general, the potential for adverse effects must be weighed against the risk of uncontrolled asthma; to date evidence supports the use of inhaled corticosteroids, especially at low and medium doses.

#### Local Adverse Effects

Oral candidiasis (thrush) is one of the most common adverse effects of inhaled corticosteroids. Positive throat cultures of Candida can be identified in about 45 to 58 percent of patients, whereas clinical thrush is diagnosed in only 0 to 34 percent of patients (Rinehart et al. 1975; Toogood et al. 1980; Shaw and Edmunds 1986). With lower dosages of inhaled corticosteroids, candidiasis is uncommon (5 percent) (Rinehart et al. 1975), although it is more frequent in adults than in children. Prevention and treatment: Use a spacer/holding chamber to reduce the incidence of colonization and clinical thrush, rinse mouth with water after inhalation (Selroos and Halme 1991), and administer inhaled corticosteroids less frequently (bid vs. qid). Topical or oral antifungal agents should be used to treat active infections.

Dysphonia is reported in 5 to 50 percent of patients using inhaled corticosteroids and is associated with vocal stress and increasing dosages of inhaled corticosteroids (Toogood et al. 1980). Prevention and treatment: Use a spacer/holding chamber, temporarily reduce dosage, or rest for vocal stress.

Reflex cough and bronchospasm can be reduced by slower rates of inspiration and/or use of a spacer/holding chamber or pretreatment with an inhaled beta_2_-agonist. There is no convincing evidence that the routine use of an inhaled beta_2_-agonist prior to each dose of inhaled corticosteroids increases intrapulmonary delivery of the inhaled corticosteroid or reduces dosage requirement.

#### Systemic Adverse Effects

##### Linear Growth

The potential effects of inhaled corticosteroids on children's growth are important because the drugs are more likely to be used for longer periods of time, although it is recognized that poorly controlled asthma itself may result in retarded linear growth. Growth in children with asthma who have not received any form of corticosteroid therapy may be influenced by concomitant atopy, asthma severity, and being male, among other factors (Kamada and Szefler 1995; Allen 1996). Indeed, childhood asthma appears to be associated with delayed maturation and a longer period of reduced growth prior to puberty. Although this could be viewed as growth suppression, these delays do not appear to compromise the attainment of final predicted adult heights (Balfour-Lynn 1986; Allen 1996).

Key Points: Inhaled Corticosteroids and Linear Growth in Children

- The potential risks of inhaled corticosteroids are well balanced by their benefits.
- Growth rates are highly variable in children. Short-term evaluations may not be predictive of attaining final adult height.
- Poorly controlled asthma may delay growth in children.
- In general, children with asthma tend to have longer periods of reduced growth rates prior to puberty (males > females).
- The potential for adverse effects on linear growth from inhaled corticosteroids appears to be dose dependent. In treating children with mild-to-moderate persistent asthma, medium-dose inhaled corticosteroid therapy may be associated with a possible, but not predictable, adverse effect on linear growth. The clinical significance of this potential systemic effect has yet to be determined. High doses of inhaled corticosteroids have greater potential for growth suppression.
- Use of high doses of inhaled corticosteroids with children with severe persistent asthma has significantly less potential for having an adverse effect on linear growth than oral systemic corticosteroids.
- A majority of studies of the use of inhaled corticosteroids by children have not demonstrated an effect on growth, but a few have identified growth delay. Some caution (e.g., monitoring growth, stepping down therapy when possible) is suggested while this issue is studied further.

Because of these numerous confounding factors, evaluating the effects of systemic or inhaled corticosteroids on growth in children with asthma has been challenging and has led to contradictory findings.

A few studies of children with asthma have identified some growth delay in those treated with inhaled corticosteroids, suggesting that some caution may be prudent until this important issue can be studied further. A 1-year controlled trial comparing children with mild-to-moderate asthma receiving either inhaled beclomethasone (400 mcg per day, administered without a spacer/holding chamber) or oral theophylline demonstrated slower growth in children receiving beclomethasone (Tinkelman et al. 1993). In a placebo-controlled, community-based 7-month study of 7- to 9-year-old children to determine the effect on growth during treatment with beclomethasone at 400 mcg/day, growth was significantly decreased in both males and females, and there was no evidence of catchup growth during a 5-month washout period (Doull et al. 1995). However, the results of this short-term study may not reflect effects on long-term growth.

A recent meta-analysis of the influence of inhaled beclomethasone in the attainment of expected adult height did not find any significant adverse effects regardless of dose, duration of asthma, or disease severity (Allen et al. 1994). An uncontrolled followup study (mean duration of 2.7 years, range of 1 to 5 years) of prepubertal children with moderate asthma found no effect of inhaled budesonide (800 mcg mean daily dose) on long-term growth (Ninan and Russell 1992). A majority of studies do not demonstrate a negative effect on growth with dosages of 400 to 800 mcg a day (Wolthers 1996; Kamada et al. 1996; Kamada and Szefler 1995; Barnes and Pederson 1993).

##### Bone Metabolism/Osteoporosis

The few published observations regarding the effect of inhaled corticosteroids on bone metabolism and osteoporosis are complicated by oral corticosteroid use and small patient populations (Jennings et al. 1991a, 1991b; Toogood et al. 1991). The effects of inhaled corticosteroid on markers of skeletal metabolism—serum osteocalcin, serum alkaline phosphatase, and urinary hydroxyproline:creatinine ratio—are equivocal (Hodsman et al. 1991; Jennings et al. 1991a; Ali et al. 1991). The clinical implications in terms of risk of osteoporosis and fracture after long-term use of inhaled corticosteroids are still unknown (Jennings et al. 1991b; Pouw et al. 1991). Although low and medium dosages of inhaled corticosteroids appear to have no major adverse effects on any clinically important measure of bone metabolism (Toogood et al. 1991, 1995), a dose-dependent, yet significant, reduction in bone mineral content of subjects with asthma has been associated with inhaled corticosteroid use (Packe et al. 1992; Puolijoki et al. 1992; Toogood et al. 1988). Elderly female patients may be more at risk due to preexisting osteoporosis, previous use of oral corticosteroids, a sedentary lifestyle, and the normal changes of estrogen in aging that affect calcium utilization. However, the risk of uncontrolled asthma, which may unnecessarily limit the patient's mobility and activities, must be weighed against the limited risks of using inhaled corticosteroids.

##### Prevention and treatment

Concurrent treatment with calcium supplements and vitamin D (and estrogen replacement where appropriate) is reasonable.

##### Disseminated Varicella

Although high doses of inhaled corticosteroids theoretically present risks similar to those of systemic corticosteroids, the reports of disseminated varicella in patients receiving only inhaled corticosteroids are rare, causality is not clear, and there is no evidence that recommended doses of inhaled corticosteroids are immunosuppressive. Cases have been reported of children with severe persistent asthma on immunosuppressive doses of systemic corticosteroids developing fatal disseminated disease from varicella infection (Kasper and Howe 1990; Silk et al. 1988). Other case reports indicate complications for patients with Strongyloides or tuberculosis who take high doses of systemic corticosteroids.

##### Prevention and treatment

Children who require episodic therapy with systemic corticosteroids who have not had clinical varicella should receive the varicella vaccine. The vaccine should not be administered to patients who are receiving immunosuppressive doses of systemic corticosteroids (2 mg/kg or more of prednisone equivalent or 20 mg/day of prednisone for more than 1 month), unless this dosage is discontinued for at least 1 month. Children who have completed a short prednisone course may receive varicella vaccine without delay (American Academy of Pediatrics 1995; CDC 1994). Children and adults on treatment with immunosuppressive doses of corticosteroids who have not been immunized against varicella and are exposed to varicella infection are candidates for zoster immunoglobulin and therapy with oral acyclovir. Should they develop clinical varicella, intravenous acyclovir with or without zoster immunoglobulin should be given.

Dermal thinning and increased ease of skin bruising have been observed in elderly subjects treated with inhaled corticosteroids. The effect is dose dependent, but the threshold dose is variable (Capewell et al. 1990).

##### Hypothalamic Pituitary Axis (HPA) Function

The issue of inhaled corticosteroid effects on HPA function is complex and requires further study. Several studies indicate that low-to-medium doses of inhaled corticosteroids do not appear to have significant effects on HPA function (Doull et al. 1995; Goldstein and Konig 1983). However, some studies showed that, compared with placebo, both beclomethasone and budesonide reduced the 24-hour urinary cortisol excretion even in doses as low as 400 to 500 mcg daily (Tabachnik and Zadik 1991; Prahl 1991). At higher doses, there appears to be a dose-dependent effect on different measures of HPA function (Kamada et al. 1996; Brown et al. 1993). Fluticasone caused greater adrenal suppression at doses of 400 to 2,000 mcg than budesonide in equivalent doses (Clark et al. 1996; Boorsma et al. 1996). The clinical significance, if any, of these findings is not known.

##### Cataracts

Although cataracts are a documented adverse effect of systemic corticosteroids, there appears to be no association between inhaled corticosteroids and posterior subcapsular cataracts in adults (Toogood et al. 1993) or children (Simons et al. 1993; Rooklin et al. 1979).

##### Glucose Metabolism

In a study of children, inhaled corticosteroids at dosages from 400 to 1,000 mcg/day (budesonide) failed to affect fasting glucose or glycated hemoglobin (Turpeinen et al. 1991). At 1,000 mcg/day, a significantly greater rise in fasting serum insulin levels and glucose during a glucose tolerance test was noted, but results remained within normal limits.

## References

Agertoft L, Pedersen S. Importance of the inhalation device on the effect of budesonide. Arch Dis Child. 1993;69:130-3. [pmid: 8024295].
Ahrens R, Lux C, Bahl T, Han S H. Choosing the metered-dose inhaler spacer or holding chamber that matches the patient's need: evidence that the specific drug being delivered is an important consideration. J Allergy Clin Immunol. 1995;96:288-94. [pmid: 7636073].
Alexander A G, Barnes N C, Kay A B. Trial of cyclosporin in corticosteroid-dependent chronic severe asthma. Lancet. 1992;339:324-8. [pmid: 1346410].
Ali N J, Capewell J, Ward M J. Bone turnover during high dose inhaled corticosteroid treatment. Thorax. 1991;46:160-4. [pmid: 2028429].
Allen DB. Growth suppression by glucocorticoid therapy. In: Vassallo J, ed. Endocrinology and Metabolism Clinics in North America. Philadelphia: W.B. Saunders Co. 1996;699–717.
Allen D B, Mullen M, Mullen B. A meta-analysis of the effect of oral and inhaled corticosteroids on growth. J Allergy Clin Immunol. 1994;93:967-76. [pmid: 8006318].
Alton E, Norris A A. Chloride transport and the actions of nedocromil sodium and cromolyn sodium in asthma. J Allergy Clin Immunol. 1996;98:S102-6. [pmid: 8939184].
American Academy of Pediatrics Committee on Infectious Diseases. Recommendations for the use of live attenuated varicella vaccine. Pediatrics. 1995;5:791-6.
Balfour-Lynn L. Growth and childhood asthma. Arch Dis Child. 1986;61(11):1049-55. [pmid: 3098185].
Barnes N C, Marone G, Di Maria G U, Visser S, Utama I, Payne S L. A comparison of fluticasone propionate, 1 mg daily, with beclomethasone dipropionate, 2 mg daily, in the treatment of severe asthma. Eur Respir J. 1993;6:877-85. [pmid: 8339809].
Barnes P J, Pedersen S. Efficacy and safety of inhaled corticosteroids in asthma. Am Rev Respir Dis. 1993;148:S1-S26. [pmid: 8214958].
Beam W R, Weiner D E, Martin R J. Timing of prednisone and alterations of airways inflammation in nocturnal asthma. Am Rev Respir Dis. 1992;146(6):1524-30. [pmid: 1456570].
Becker A B, Simons F E. Formoterol, a new long-acting selective beta_2_-adrenergic receptor agonist: double-blind comparison with salbutamol and placebo in children with asthma. J Allergy Clin Immunol. 1989;84:891-5. [pmid: 2574732].
Bernstein I L, Bernstein D I, Dubb J W, Faiferman I, Wallin B, participants of the Auranofin Multicenter Drug Trial. A placebo-controlled multicenter study of auranofin in the treatment of patients with corticosteroid-dependent asthma. J Allergy Clin Immunol. 1996;98:317-24. [pmid: 8757209].
Bhagat R, Swystun V A, Cockcroft D W. Salbutamol-induced increased airway responsiveness to allergen and reduced protection versus methacholine: dose response. J Allergy Clin Immunol. 1996;97:47-52. [pmid: 8568137].
Boorsma M, Andersson N, Larsson P, Ullman A. Assessment of the relative systemic potency of inhaled fluticasone and budesonide. Eur Respir J. 1996;9:1427-32. [pmid: 8836654].
Booth H, Richmond I, Ward C, Gardiner P V, Harkawat R, Walters E H. Effect of high dose inhaled fluticasone propionate on airway inflammation in asthma. Am J Respir Crit Care Med. 1995;152:45-52. [pmid: 7599861].
Britton M G, Earnshaw J S, Palmer J B D. A twelve month comparison of salmeterol with salbutamol in asthmatic patients. Eur Respir J. 1992;5:1062-7. [pmid: 1426215].
Brown P H, Matusiewicz S P, Shearing C, Tibi L, Greening A P, Crompton G K. Systemic effects of high dose inhaled steroids: comparison of beclomethasone dipropionate and budesonide in healthy subjects. Thorax. 1993;48:967-73. [pmid: 8256242].
Brown P H, Blundell G, Greening A P, Crompton G K. Do large volume spacer devices reduce the systemic effects of high dose inhaled corticosteroids?. Thorax. 1990;45:736-9. [pmid: 2247863].
Busse W W. What role for inhaled steroids in chronic asthma?. Chest. 1993;104:1565-71. [pmid: 8222825].
Capewell S, Reynolds S, Shuttleworth D, Edwards C, Finlay A Y. Purpura and dermal thinning associated with high dose inhaled corticosteroids. BMJ. 1990;300:1548-51. [pmid: 2372620].
Castle W, Fuller R, Hall J, Palmer J. Serevent nationwide surveillance study: comparison of salmeterol with salbutamol in asthmatic patients who require regular bronchodilator treatment. BMJ. 1993;306:1034-7. [pmid: 8098238].
Centers for Disease Control and Prevention. General recommendations on immunization. Morb Mortal Wkly Rep 1994;Jan 28;43(RR-1):1–38.
Chapman K R, Verbeek P R, White J G, Rebuck A S. Effect of a short course of prednisone in the prevention of early relapse after the emergency room treatment of acute asthma. N Engl J Med. 1991;324:788-94. [pmid: 1997850].
Cheung D, Timmers M C, Zwinderman A H, Bel E H, Dijkman J H, Sterk P J. Long-term effects of a long-acting beta_2_-adrenoceptor agonist, salmeterol, on airway hyperresponsiveness in patients with mild asthma. N Engl J Med. 1992;327:1198-203. [pmid: 1357550].
Clark B. General pharmacology, pharmacokinetics, and toxicology of nedocromil sodium. J Allergy Clin Immunol. 1993;92:200-2. [pmid: 8393030].
Clark C E, Ferguson A D, Siddorn J A. Respiratory arrests in young asthmatics on salmeterol. Respir Med. 1993;87(3):227-8. [pmid: 8497705].
Clark D J, Grove A, Cargill R I, Lipworth B J. Comparative adrenal suppression with inhaled budesonide and fluticasone propionate in adult asthmatic patients. Thorax. 1996;51:262-6. [pmid: 8779128].
Cockcroft D W, McParland C P, Britto S A, Swystun V a, Rutherford B C. Regular inhaled salbutamol and airway responsiveness to allergen. Lancet. 1993;342:833-7. [pmid: 8104272].
Cockcroft D W, O'Byrne P M, Swystun V A, Bhagat R. Regular use of inhaled albuterol and the allergen-induced late asthmatic response. J Allergy Clin Immunol. 1995;96:44-9. [pmid: 7622762].
Connett G J, Warde C, Wooler E, Lenney W. Use of budesonide in severe asthmatics aged 1–3 years. Arch Dis Child. 1993;69:351-5. [pmid: 8215545].
Connett G J, Warde C, Wooler E, Lenney W. Prednisolone and salbutamol in the hospital treatment of acute asthma. Arch Dis Child. 1994;70:170-3. [pmid: 8135557].
Creticos P, Burk J, Smith L, Comp R, Norman P, Findlay S. The use of twice daily nedocromil sodium in the treatment of asthma. J Allergy Clin Immunol. 1995;95:829-36. [pmid: 7722163].
Crompton G, Duncan J. Clinical assessment of a new breath-actuated inhaler. Practitioner. 1989;233:268-9. [pmid: 2587490].
D'Alonzo G E, Nathan R A, Henochowicz S, Morris R J, Ratner P, Rennard S I. Salmeterol xinafoate as maintenance therapy compared with albuterol in patients with asthma. JAMA. 1994;271:1412-6. [pmid: 7909853].
Dahl R, Lundback E, Malo J L, et al. A dose-ranging study of fluticasone propionate in adult patients with moderate asthma. Chest. 1993;104:1352-8. [pmid: 8222787].
Dahlen B, Zetterstrom O, Bjorck T, Dahlen S E. The leuktriene-antagonist IC:204, 219 inhibits the early airway reaction to cumulative bronchial challenge with allergen in atopic asthmatics. Eur Respir J. 1994;7:324-31. [pmid: 8162986].
de Benedictis F M, Tuteri G, Pazzelli P, Bertotto A, Bruni L, Vaccaro R. Cromolyn versus nedocromil: duration of action in exercise-induced asthma in children. J Allergy Clin Immunol. 1995;96:510-4. [pmid: 7560663].
Dixon C M S, Barnes P J. Bradykinin-induced bronchoconstriction: inhibition by nedocromil sodium and sodium cromoglycate. Br J Clin Pharmacol. 1989;27:831-6. [pmid: 2547408].
Djukanovic R, Wilson T W, Britten K M, et al. Effect of an inhaled corticosteroid on airway inflammation and symptoms of asthma. Am Rev Respir Dis. 1992;145:669-74. [pmid: 1546849].
Dorsch W, Wagner H. New antiasthmatic drugs from traditional medicine?. Int Arch Allergy Anal Immunol. 1991;94:262-5.
Doull I J M, Freezer N J, Holgate S T. Growth of pre-pubertal children with mild asthma treated with inhaled beclomethasone dipropionate. Am J Respir Crit Care Med. 1995;151:1715-9. [pmid: 7767512].
Drazen J M, Israel E, Boushey H A, et al. Comparison of regularly scheduled with as-needed use of albuterol in mild asthma. N Engl J Med. 1996;335:841-7. [pmid: 8778601].
Duddridge M, Ward C, Hendrick D J, Walters E H. Changes in bronchoalveolar lavage inflammatory cells in asthmatic patients with high dose inhaled beclomethasone dipropionate. Eur Respir J. 1993;6:487-97.
Eady R P. The pharmacology of nedocromil sodium. Eur J Respir Dis. 1986;147(Suppl):112-9.
Eisenberg D M, Kessler R E C, Foster C, Norlock F E, Calkins D R, Delbannco T L. Unconventional medicine in the United States. Prevalence, costs, and patterns of use. N Engl J Med. 1993;328:246-52. [pmid: 8418405].
Ernst P, Habbick B, Suissa S, et al. Is the association between inhaled beta-agonist use and life-threatening asthma because of confounding by severity?. Am Rev Respir Dis. 1993;148:75-9. [pmid: 8100409].
Erzurum S C, Leff J A, Cochran J E, et al. Lack of benefit of methotrexate in severe, steroid-dependent asthma. Ann Intern Med. 1991;114:353-60. [pmid: 1992876].
Everard M L, Clark A R, Milner A D. Drug delivery from holding chambers with attached facemask. Arch Dis Child. 1992;67:580-5. [pmid: 1599292].
Fabbri L, Burge P S, Croonenborgh L. on behalf of an International Study Group, et al. . Comparison of fluticasone propionate with beclomethasone dipropionate in moderate to severe asthma treated for one year. Thorax. 1993;48:817-23. [pmid: 8211872].
Fanta C H, Rossing T H, McFadden E R Jr. Glucocorticoids in acute asthma. A critical controlled trial. Am J Med. 1983;74:845-51. [pmid: 6340496].
Fitzpatrick M F, Mackay T, Driver H, Douglas N J. Salmeterol in nocturnal asthma: a double blind, placebo controlled trial of a long acting inhaled beta_2_-agonist. BMJ. 1990;301:1365-8. [pmid: 1980220].
Fuglsang G, Pedersen S. Comparison of Nebuhaler and nebulizer treatment of acute severe asthma in children. Eur J Respir Dis. 1986;69:109-13. [pmid: 3758239].
Fung K P, Chow O K, So S Y. Attenuation of exercise-induced asthma by acupuncture. Lancet. 1986;2:1419-22. [pmid: 2878275].
Gaddy J N, Margolskee D J, Bush R K, Williams V C, Busse W W. Bronchodilation with a potent and selective leukotriene D4 (LTD4) receptor antagonist (MK-571) in patients with asthma. Am Rev Respir Dis. 1992;146(2):358-63. [pmid: 1489125].
Goldstein D E, Konig P. Effect of inhaled beclomethasone dipropionate on hypothalamic-pituitary-adrenal axis function in children with asthma. Pediatrics. 1983;72:60-4. [pmid: 6866593].
Gonzalez J P, Brogden R N. Nedocromil sodium. A preliminary review of its pharmacodynamic and pharmacokinetic properties, and therapeutic efficacy in the treatment of reversible obstructive airways disease. Drugs. 1987;34:560-77. [pmid: 2826101].
Goren A, Noviski N, Avital A, et al. Assessment of the ability of young children to use a powder inhaler device (Turbuhaler). Pediatr Pulmonol. 1994;18:77-80. [pmid: 7970922].
Green C P, Price J F. Prevention of exercise induced asthma by inhaled salmeterol xinafoate. Arch Dis Child. 1992;67:1014-7. [pmid: 1355645].
Greening A P, Wind P, Northfield M, Shaw G. Added salmeterol versus higher-dose corticosteroid in asthma patients with symptoms on existing inhaled corticosteroid. Lancet. 1994;344:219-24. [pmid: 7913155].
Gross N J. Ipratropium bromide. N Engl J Med. 1988;319:486-94. [pmid: 2970009].
Gustafsson P, Tsanakas J, Gold M, Primhak R, Radford M, Gillies E. Comparison of the efficacy and safety of inhaled fluticasone 200 mcg/day with inhaled beclomethasone dipropionate 400 mcg/day in mild and moderate asthma. Arch Dis Child. 1993;69:206-11. [pmid: 8215522].
Haahtela T, Jarvinen M, Kava T, et al. Comparison of a beta_2_-agonist, terbutaline, with an inhaled corticosteroid, budesonide, in newly detected asthma. N Engl J Med. 1991;325:388-92. [pmid: 2062329].
Hendeles L, Harman E, Huang D, O'Brien R, Blake K, Delafuente J. Theophylline attenuation of airway responses to allergen: comparison with cromolyn metered-dose inhaler. J Allergy Clin Immunol. 1995;95:505-14. [pmid: 7852666].
Henderson W R Jr. The role of leukotrienes in inflammation. Ann Intern Med. 1994;121:684-97. [pmid: 7944079].
Henriksen J M, Agertoft L, Pedersen S. Protective effect and duration of action of inhaled formoterol and salbutamol on exercise-induced asthma in children. J Allergy Clin Immunol. 1992;89:1176-82. [pmid: 1351489].
Higgins R M, Cookson W, Lane D J, John S M, McCarthy G L, McCarthy S T. Cardiac arrythmias caused by nebulized beta-agonist therapy. Lancet. 1987;2:863-4. [pmid: 2889068].
Hodsman A B, Toogood J H, Jennings B, Fraher L J, Baskerville J C. Differential effects of inhaled budesonide and oral prednisolone on serum osteocalcin. J Clin Endocrinol Metab. 1991;72:530-40. [pmid: 1997509].
Israel E, Fischer A R, Rosenberg M A, et al. The pivotal role of 5-lipoxygenase products in the reaction of aspirin-sensitive asthmatics to aspirin. Am Rev Respir Dis. 1993;148:1447-51. [pmid: 8256883].
Israel E, Cohn J, Dubé L, Drazen J M. Effect of treatment with zileuton, a 5-lipoxygenase inhibitor, in patients with asthma. JAMA. 1996;275:931-6. [pmid: 8598621].
Jarjour N, Gelfand E, McGill K, Busse WW. Alternative anti-inflammatory and immunomodulatory therapy. In: Szefler J, Leung DYM, eds. Severe Asthma. Pathogenesis and Clinical Management. New York: Marcel Dekker, 1996, pp. 333-69.
Jeffery P K, Godfrey R W, Adelroth E, Nelson F, Rogers A, Johansson S A. Effects of treatment on airway inflammation and thickening of basement membrane reticular collagen in asthma. Am Rev Respir Dis. 1992;145:890-9. [pmid: 1554218].
Jennings B H, Andersson K E, Johansson S A. The assessment of the systemic effects of inhaled glucocorticosteroids. The effects of inhaled budesonide vs oral prednisolone on calcium metabolism. Eur J Clin Pharmacol. 1991a;41:11-6. [pmid: 1782971].
Jennings B H, Andersson K E, Johansson S A. Assessment of systemic effects of inhaled glucocorticosteroids: comparison of the effects of inhaled budesonide and oral prednisolone on adrenal function and markers of bone turnover. Eur J Clin Pharmacol. 1991b;40:77-82. [pmid: 2060551].
Jones A H, Langdon C G, Lee P S, et al. Pulmicort Turbuhaler once daily as initial prophylactic therapy for asthma. Respir Med. 1994;88:293-9. [pmid: 8036292].
Juniper E F, Kline P A, Morris M M, Hargreave F E. Airway constriction by isocapnic hyperventilation of cold, dry air: comparison of magnitude and duration of protection by nedocromil sodium and sodium cromoglycate. Clin Allergy. 1987;17:523-8. [pmid: 2830047].
Juniper E F, Johnston P R, Borkhoff C M, Guyatt G H, Boulet L P, Haukioja A. Quality of life in asthma clinical trials: comparison of salmeterol and salbutamol. Am J Respir Crit Care Med. 1995;151:66-70. [pmid: 7812574].
Kamada A K, Hill M R, Ikle D N, Brenner A M, Szefler S J. Efficacy and safety of low-dose troleandomycin therapy in children with severe, steroid-requiring asthma. J Allergy Clin Immunol. 1993;91:873-82. [pmid: 8473676].
Kamada A K, Szefler S J. Glucocorticoids and growth in asthmatic children. Pediatr Allergy Immunol. 1995;6:145-54. [pmid: 8750310].
Kamada A K, Szefler S J, Martin R J, et al. and the Athma Clinical Research Network. Issues in the use of inhaled glucocorticoids. Am J Respir Crit Care Med. 1996;153:1739-48. [pmid: 8665030].
Kasper W J, Howe P M. Fatal varicella after a single course of corticosteroids. Pediatr Infect Dis J. 1990;9:729-32. [pmid: 2235146].
Kemp J P, Furukawa C T, Bronsky E A, et al. Albuterol treatment for children with asthma: a comparison of inhaled powder and aerosol. J Allergy Clin Immunol. 1989;83:697-702. [pmid: 2647819].
Kerrebijn K F, van Essen-Zandvliet E E, Neijens H J. Effect of long-term treatment with inhaled corticosteroids and beta-agonists on the bronchial responsiveness in children with asthma. J Allergy Clin Immunol. 1987;79(4):653-9. [pmid: 3549842].
Kerstjens H A, Brand P L, Hughes M D, et al. A comparison of bronchodilator therapy with or without inhaled corticosteroid therapy for obstructive airways disease. N Engl J Med. 1992;327:1413-9. [pmid: 1357553].
Kesten S, Elias M, Cartier A, Chapman K R. Patient handling of a multidose dry powder inhalation device for albuterol. Chest. 1994;105:1077-81. [pmid: 8162728].
Kidney J, Dominguez M, Taylor P M, Rose M, Chung K F, Barnes P J. Immunomodulation by theophylline in asthma. Am J Respir Crit Care Med. 1995;151:1907-14. [pmid: 7767539].
Kim C S, Eldridge M A, Sackner M A. Oropharyngeal deposition and delivery aspects of metered-dose inhaler aerosols. Am Rev Respir Dis. 1987;135:157-64. [pmid: 3800143].
Klaustermeyer W B, Noritake D T, Kwong F K. Chrysotherpay in the treatment of corticosteroid-dependent asthma. J Allergy Clin Immunol. 1987;79:720-5. [pmid: 3106448].
Kleijnen J, ter Riet G, Knipschild P. Acupuncture and asthma: a review of controlled trials. Thorax. 1991;46:799-802. [pmid: 1771601].
Laitinen L A, Laitinen A, Haahtela T. A comparative study of the effects of an inhaled corticosteroid, budesonide, and a beta_2_-agonist, terbutaline, on airway inflammation in newly diagnosed asthma: a randomized, double-blind, parallel-group controlled trial. J Allergy Clin Immunol. 1992;90:32-42. [pmid: 1629507].
Laitinen L A, Laitinen A, Heino M, Haahtela T. Eosinophilic airway inflammation during exacerbation of asthma and its treatment with inhaled corticosteroid. Am Rev Respir Dis. 1991;143(2):423-7. [pmid: 1990962].
Lal S, Dorow P D, Venho K K, Chatterjee S S. Nedocromil sodium is more effective than cromolyn sodium for the treatment of chronic reversible obstructive airway disease. Chest. 1993;104:438-47. [pmid: 8393398].
Levy J, Zalkinder I, Kuperman O, et al. Effect of prolonged use of inhaled steroids on the cellular immunity of children with asthma. J Allergy Clin Immunol. 1995;95:806-12. [pmid: 7722159].
Lipworth B J. New perspectives on inhaled drug delivery and systemic bioactivity. Thorax. 1995;50:105-10. [pmid: 7701444].
Lotvall J, Lunde H, Ullman A, Tornqvist H, Svedmyr N. Twelve months treatment with inhaled salmeterol in asthmatic patients. Effects on beta_2_-receptor function and inflammatory cells. Allergy. 1992;47:477-83. [pmid: 1362481].
Lundback B, Rawlinson D W, Palmer J B. Twelve month comparison of salmeterol and salbutamol as dry powder formulations in asthmatic patients. European Study Group. Thorax. 1993;48(2):148-53. [pmid: 8493629].
Maesen F P, Smeets J J, Gubbelmans H L, Zweers P G. Formoterol in the treatment of nocturnal asthma. Chest. 1990;98:866-70. [pmid: 1976487].
Mann R D, Kubota K, Pearce G. Salmeterol: a study by prescription-event monitoring in a UK cohort of 15,407 patients. J Clin Epidemiol. 1996;49(2):247-50. [pmid: 8606326].
Mazer B D, Gelfand E W. An open-label study of high-dose intravenous immunoglobin in severe childhood asthma. J Allergy Clin Immunol. 1991;87:976-83. [pmid: 2026848].
McFadden E R Jr. Perspectives in beta_2_-agonist therapy: vox clamantis in deserto vel lux in tenebris?. J Allergy Clin Immunol. 1995;95:641-51. [pmid: 7897145].
McGill K A, Joseph B, Busse W W. Corticosteroids in the treatment of asthma. Practical recommendations. Clin Immunother. 1995;4:16-48.
Melchor R, Biddiscombe M F, Mak V H F, Short M D, Spiro S G. Lung deposition patterns of directly labelled salbutamol in normal subjects and in patients with reversible airflow obstruction. Thorax. 1993;48:506-11. [pmid: 8322237].
Meltzer S S, Hasday J D, Cohn J, Bleecker E R. Inhibition of exercise-induced bronchospasm by zileuton: a 5-lipoxygenase inhibitor. Am J Respir Crit Care Med. 1996;153:931-5. [pmid: 8630575].
Morice A. Adulterated “homeopathic” care for asthma. Lancet. 1986;1:862-3. [pmid: 2870348].
Mullarkey M E, Blumenstein B A, Andrade W P, Bailey G A, Olason I, Wetzel C E. Methotrexate in the treatment of corticosteroid-dependent asthma. N Engl J Med. 1988;318:603-7. [pmid: 3278232].
Mullen M L, Mullen B, Carey M. The association between beta_2_-agonist use and death from asthma. JAMA. 1993;270:1842-5. [pmid: 8105113].
Muranaka M, Miyamoto T, Shida T, et al. Gold salt in the treatment of bronchial asthma—a double-blind study. Ann Allergy. 1978;40:132-7. [pmid: 415643].
Nelson H S, Hamilos D L, Corsello P R, Levesque N V, Buchmeier A D, Bucher B L. A double-blind study of troleandomycin and methylprednisolone in asthmatic subjects who require daily corticosteroids. Am Rev Respir Dis. 1993;147:398-404. [pmid: 8430965].
Newhouse M T, Dolovich M B. Control of asthma by aerosols. N Engl J Med. 1986;315:870-4. [pmid: 2875391].
Newman K B, Mason U G, Buchmeier A, Schmaling K B, Corsello P, Nelson H S. Failure of colchicine to reduce inhaled triamcinolone in patients with asthama. J Allergy Clin Immunol. 1997;99:176-8. [pmid: 9042041].
Newman S P, Millar A B, Lennard-Jones T R, Moren F, Clarke S W. Improvement of pressurized aerosol deposition with Nebuhaler spacer device. Thorax. 1984;39:935-41. [pmid: 6440305].
Newman S P, Moren F, Pavla D, Little F, Clarke S W. Deposition of pressurized suspension aerosols inhaled through extension devices. Am Rev Respir Dis. 1981;124:317-20. [pmid: 7283266].
Newman S P, Weisz A W B, Talaee N, Clarke S W. Improvement of drug delivery with a breath actuated pressurised aerosol for patients with poor inhaler technique. Thorax. 1991;46:712-6. [pmid: 1750017].
Ninan T K, Russell G. Asthma, inhaled corticosteroid treatment, and growth. Arch Dis Child. 1992;67(6):703-5. [pmid: 1626989].
Noonan M, Chervinsky P, Busse W W, et al. Fluticasone propionate reduces oral prednisone use while it improves asthma control and quality of life. Am J Respir Crit Care Med. 1995;152:1467-73. [pmid: 7582278].
Novembre G, Frongia G F, Veneruso G, Vierucci A. Inhibition of exercise-induced asthma (EIA) by nedocromil sodium and sodium cromoglycate in children. Pediatr Allergy Immunol. 1994;5:107-10. [pmid: 8087189].
O'Callaghan C, Cant M, Robertson C. Delivery of beclomethasone dipropionate from a spacer device: what dose is available for inhalation?. Thorax. 1994;49:961-4. [pmid: 7974311].
O'Connor B J, Aikman S L, Barnes P J. Tolerance to the nonbronchodilator effects of inhaled beta_2_-agonists in asthma. N Engl J Med. 1992;327:1204-8. [pmid: 1357551].
O'Hickey S P, Rees P J. High-dose nedocromil sodium as an addition to inhaled corticosteroids in the treatment of asthma. Respir Med. 1994;88:499-502. [pmid: 7972972].
Packe G E, Douglas J G, McDonald A F, Robins S P, Reid D M. Bone density in asthmatic patients taking high dose inhaled beclomethasone dipropionate and intermittent systemic corticosteroids. Thorax. 1992;47(6):414-7. [pmid: 1496498].
Pauwels R A. New aspects of the therapeutic potential of theophylline in asthma. J Allergy Clin Immunol. 1989;83:548-53. [pmid: 2645351].
Pearlman D S, Chervinsky P, LaForce C, et al. A comparison of salmeterol with albuterol in the treatment of mild-to-moderate asthma. N Engl J Med. 1992;327:1420-5. [pmid: 1357554].
Pedersen S, Mortensen S. Use of different inhalation devices in children. Lung. 1990;168(Suppl):653-7. [pmid: 2117175].
Pedersen S, Hansen O R, Fuglsang G. Influence of inspiratory flow rate upon the effect of a Turbuhaler. Arch Dis Child. 1990;65:308-10. [pmid: 2185701].
Pedersen S, Hansen O R. Budesonide treatment of moderate and severe asthma in children: a dose-response study. J Allergy Clin Immunol. 1995;95:29-33. [pmid: 7822661].
Pincus D J, Szefler S J, Ackerson L M, Martin R J. Chronotherpay of asthma with inhaled steroids: the effect of dosage timing on drug efficacy. J Allergy Clin Immunol. 1995;95:1172-8. [pmid: 7797785].
Pouw E M, Prummel M F, Oosting H, Roos C M, Endert E. Beclomethasone inhalation decreases serum osteocalcin concentrations. BMJ. 1991;302:627-8. [pmid: 2012877].
Prahl P. Adrenocortical suppression following treatment with beclomethasone dipropionate and budesonide. Clin Exp Allergy. 1991;21:145-6. [pmid: 2021872].
Prahl P, Jenson T. Decreased adrenocortical suppression utilizing the nebuhaler for inhalation of steroid aerosols. Clin Allergy. 1987;17:393-8. [pmid: 3677366].
Puolijoki H, Liippo K, Herrala J, Salmi J, Tala E. Inhaled beclomethasone decreases serum osteocalcin in postmenopausal asthmatic women. Bone. 1992;13(4):285-8. [pmid: 1389567].
Rafferty P, Tucker L G, Frame M H, Fergusson R J, Biggs B A, Crompton G K. Comparison of budesonide and beclomethasone dipropionate in patients with severe chronic asthma: assessment of relative prednisolone-sparing effects. Br J Dis Chest. 1985;79:244-50. [pmid: 3893509].
Ramage L, Lipworth B J, Ingram C G, Cree I A, Dhillon D P. Reduced protection against exercise induced bronchoconstriction after chronic dosing with salmeterol. Respir Med. 1994;88(5):363-8. [pmid: 7913549].
Reilly D T, McSharry C, Taylor M A, Aitchison T. Is homeopathy a placebo response? Controlled trial of homeopathic potency, with pollen in hayfever as model. Lancet. 1986;2:881-6. [pmid: 2876326].
Rinehart J J, Sagone A L, Balcerzak S P, Ackerman G A, LoBuglio A F. Effects of corticosteroid therapy on human monocyte function. N Engl J Med. 1975;292:236-41. [pmid: 1089191].
Rooklin A R, Lampert S I, Jaeger E A, McGeady S J, Mansmann H C Jr. Posterior subcapsular cataracts in steroid-requiring asthmatic children. J Allergy Clin Immunol. 1979;63(6):383-6. [pmid: 447940].
Rossing T H, Fanta C H, Goldstein D H, Snapper J R, McFadden E R Jr. Emergency therapy of asthma: comparison of the acute effects of parenteral and inhaled sympathomimetics and infused aminophylline. Am Rev Respir Dis. 1980;122:365-71. [pmid: 7416612].
Rowe B H, Keller J L, Oxman A D. Effectiveness of steroid therapy in acute exacerbations of asthma: a meta-analysis. Am J Emerg Med. 1992;10:301-10. [pmid: 1535500].
Ruggins N R, Milner A D, Swarbrick A. An assessment of a new breath actuated inhaler device in acutely wheezy children. Arch Dis Child. 1993;68:477-80. [pmid: 8503670].
Scarfone R J, Fuchs S M, Nager A L, Shane S A. Controlled trial of oral prednisone in the emergency department treatment of children with acute asthma. Pediatrics. 1993;2:513-8. [pmid: 8414819].
Schecker M H, Wilson A F, Mukai D S, Hahn M, Crook D, Novey H S. A device for overcoming discoordination with metered-dose inhalers. J Allergy Clin Immunol. 1993;92:783-9. [pmid: 7794289].
Schwartz H J, Blumenthal M, Brady R, et al. A comparative study of the clinical efficacy of nedocromil sodium and placebo. Chest. 1996;109:945-52. [pmid: 8635375].
Sears M R, Taylor D R, Print C G, et al. Regular inhaled beta-agonist treatment in bronchial asthma. Lancet. 1990;336:1391-6. [pmid: 1978871].
Selroos O, Pietinalho A, Lofroos A, Riska H. Effect of early vs. late intervention with inhaled corticosteroids in asthma. Chest. 1995;108:1228-34. [pmid: 7587421].
Selroos O, Halme M. Effect of a volumatic spacer and mouth rinsing on systemic absorption of inhaled corticosteroids from a metered dose inhaler and dry powder inhaler. Thorax. 1991;46:891-4. [pmid: 1792636].
Shaw N J, Edmunds A T. Inhaled beclomethasone and oral candidiasis. Arch Dis Child. 1986;61:788-90. [pmid: 3740927].
Shiner R J, Nunn A J, Chung K F, Gedder D M. Randomised, double-blind, placebo-controlled trial of methotrexate in steroid-dependent asthma. Lancet. 1990;336:137-40. [pmid: 1973472].
Silk H J, Guay-Woodford L, Perez-Atayde A R, Geha R S, Broff M D. Fatal varicella in steroid-dependent asthma. J Allergy Clin Immunol. 1988;81:47-51. [pmid: 3339190].
Simons F E, Persaud M P, Gillespie C A, Cheang M, Shuckett E P. Absence of posterior subcapsular cataracts in young patients treated with inhaled glucocorticoids. Lancet. 1993;342:776-8. [pmid: 8103877].
Spector S L, Smith L J, Glass M. Effects of 6 weeks of therapy with oral doses of ICI 204,219, a leukotriene D4 receptor antagonist, in subjects with bronchial asthma. Am J Respir Crit Care Med. 1994;150:618-23. [pmid: 8087328].
Spitzer W O, Suissa S, Ernst P, et al. The use of beta-agonist and the risk of death and near death from asthma. N Engl J Med. 1992;326:501-6. [pmid: 1346340].
Storms W W, Bodman S F, Nathan R A, et al. Use of ipratropium bromide in asthma. Am J Med. 1986;81:61-6. [pmid: 2947462].
Suissa S, Ernst P, Boivin J P, et al. A cohort analysis of excess mortality in asthma and the use of inhaled beta-agonists. Am J Respir Crit Care Med. 1994;149:604-10. [pmid: 8118625].
Sullivan P, Bekir S, Jaffar Z, Page C, Jeffrey P, Costello J. Anti-inflammatory effects of low-dose oral theophylline in atopic asthma. Lancet. 1994;343:1006-8. [pmid: 7909049].
Svendsen U G, Jorgensen H. Inhaled nedocromil sodium as additional treatment to high dose inhaled corticosteroids in the management of bronchial asthma. Eur Respir J. 1991;4:992-9. [pmid: 1664346].
Tabachnik E, Zadik Z. Diurnal cortisol secretion during therapy with inhaled beclomethasone dipropionate in children with asthma. J Pediatr. 1991;118:294-7. [pmid: 1993964].
Taylor I K, O'Shaughensessy K M, Fuller R W, Dollery C T. Effect of cysteinyl-leukotriene receptor antagonist ICI 204.219 on allergen-induced bronchoconstriction and airway hyperreactivity in atopic subjects. Lancet. 1991;337:690-4. [pmid: 1672176].
Thompson N C. Nedocromil sodium: an overview. Respir Med. 1989;83:269-76. [pmid: 2558400].
Thorsson L, Edsbacker S, Conradson T B. Lung deposition of budesonide from Turbuhaler is twice that from a pressurized metered-dose inhaler P-MDI. Eur Respir J. 1994;7:1839-44. [pmid: 7828694].
Tinkelman D G, Reed C E, Nelson H S, Offord K P. Aerosol beclomethasone dipropionate compared with theophylline as primary treatment of chronic, mild to moderately severe asthma in children. Pediatrics. 1993;92:64-77. [pmid: 8516087].
Toogood J H, Jennings B, Greenway R W, Chuang L. Candidiasis and dysphonia complicating beclomethasone treatment of asthma. J Allergy Clin Immunol. 1980;65:145-53. [pmid: 7351447].
Toogood J H, Baskerville J C, Markov A E, et al. Bone mineral density and the risk of fracture in patients receiving long-term inhaled steroid therapy for asthma. J Allergy Clin Immunol. 1995;96:157-66. [pmid: 7636052].
Toogood J H, Crilly R G, Jones G, Nadeau J, Wells G A. Effect of high-dose inhaled budesonide on calcium and phosphate metabolism and the risk of osteoporosis. Am Rev Respir Dis. 1988;138(1):57-61. [pmid: 3202401].
Toogood J H, Jennings B, Hodsman A B, Baskerville J, Fraher L J. Effects of dose and dosing schedule of inhaled budesonide on bone turnover. J Allergy Clin Immunol. 1991;88:572-80. [pmid: 1918724].
Toogood J H, Markov A E, Baskerville J, Dyson C. Association of ocular cataracts with inhaled and oral steroid therapy during long-term treatment of asthma. J Allergy Clin Immunol. 1993;91:571-9. [pmid: 8436773].
Turpeinen M, Sorva R, Juntunen-Backman K. Changes in carbohydrate and lipid metabolism in children with asthma inhaling budesonide. J Allergy Clin Immunol. 1991;88:384-9. [pmid: 1890267].
Ullman A, Hedner J, Svedmyr N. Inhaled salmeterol and salbutamol in asthmatic patients. An evaluation of asthma symptoms and the possible development of tachyphalaxis. Am Rev Respir Dis. 1990;142:571-5. [pmid: 1975162].
van Essen-Zandvliet E E, Hughes M D, Waalkens H J, Duiverman E J, Pocock S J, Kerrebijn K F. Effects of 22 months of treatment with inhaled corticosteroids and/or beta_2_-agonists on lung function, airway responsiveness, and symptoms in children with asthma. Am Rev Respir Dis. 1992;146:547-54. [pmid: 1355640].
van Schayck C P, Dompeling E, van Herwaarden C L, et al. Bronchodilator treatment in moderate asthma or chronic bronchitis: continuous or on demand? A randomized controlled study. BMJ. 1991;303:1426-31. [pmid: 1837744].
Vidgren M, Kärkkäinen A, Karjalainen P, Nuutinen J, Paronen P. In vitro and in vivo deposition of drug particles from pressurized aerosol and dry powder inhaler. Drug Devel Indust Pharm. 1983;14:2649-65.
Weinberger M, Hendeles L. Theophylline in asthma. N Engl J Med. 1996;334:1380-8. [pmid: 8614425].
Wolthers O D. Long-, intermediate- and short-term growth studies in asthmatic children treated with inhaled glucocorticosteroids. Eur Respir J. 1996;9:821-7. [pmid: 8726950].
Wong C S, Cooper S, Britton J R, Tattersfield A E. Steroid sparing effect of nedocromil sodium in asthmatic patients on high doses of inhaled steroids. Clin Exp Allergy. 1993;23:370-6. [pmid: 8392897].
Woolcock A, Lundback B, Ringdal N, Jacques L A. Comparison of addition of salmeterol to inhaled steroids with doubling of the dose of inhaled steroid. Am J Respir Crit Care Med. 1996;153:1481-8. [pmid: 8630590].
Yates D H, Sussman H S, Shaw M J, Barnes P J, Chung K F. Regular formoterol treatment in mild asthma. Effect on bronchial responsiveness during and after treatment. Am J Respir Crit Care Med. 1995;152:1170-4. [pmid: 7551366].
Ziment I, Stein M. Inappropriate and unusual remedies. In: Weiss EB, Stein M, eds. Bronchial Asthma. Boston: Little, Brown and Company, 1993, pp. 1145–51.