# Control of Factors Contributing to Asthma Severity

Key Points
- Exposure of asthma patients to irritants or allergens to which they are sensitive has been shown to increase asthma symptoms and precipitate asthma exacerbations.
- For at least those patients with persistent asthma on daily medications, the clinician should:
  - Identify allergen exposures
  - Use the patient's history to assess sensitivity to seasonal allergens
  - Use skin testing or in vitro testing to assess sensitivity to perennial indoor allergens
  - Assess the significance of positive tests in context of patient's medical history
- Patients with asthma at any level of severity should avoid:
  - Exposure to allergens to which they are sensitive.
  - Exposure to environmental tobacco smoke.
  - Exertion when levels of air pollution are high.
  - Use of beta-blockers.
  - Sulfite-containing and other foods to which they are sensitive.
- Adult patients with severe persistent asthma, nasal polyps, or a history of sensitivity to aspirin or nonsteroidal anti-inflammatories should be counseled regarding the risk of severe and even fatal exacerbations from using these drugs.
- Patients should be treated for rhinitis, sinusitis, and gastroesophageal reflux, if present.
- Patients with persistent asthma should be given an annual influenza vaccine.

Differences from 1991 Expert Panel Report
- Skin testing or in vitro testing is now specifically recommended for at least those patients with persistent asthma exposed to perennial indoor allergens.
- Adult patients with severe persistent asthma, nasal polyps, or a history of sensitivity to aspirin or nonsteroidal anti-inflammatories are to be counseled regarding the risk of severe and even fatal exacerbations from using these drugs. In the 1991 report, all asthma patients were recommended to avoid aspirin.
- Routine use of chemicals to kill house-dust mites and denature the antigen is no longer recommended as a control measure.
- The discussion of tartrazine sensitivity in the 1991 version was deleted.
- Annual influenza vaccinations are now specifically recommended for patients with persistent asthma. The recommendation to consider pneumococcal vaccine was deleted.

For successful long-term asthma management, it is essential to identify and reduce exposures to relevant allergens and irritants and to control other factors that have been shown to increase asthma symptoms and/or precipitate asthma exacerbations. These factors fall into four categories: inhalant allergens, occupational exposures, nonallergic factors, and other factors. Ways to reduce the effects of these factors on asthma are discussed in this component.

- Inhalant allergens:
  - Animal allergens
  - House-dust mites
  - Cockroach allergens
  - Indoor fungi (molds)
  - Outdoor allergens
- Occupational exposures
- Irritants:
  - Tobacco smoke
  - Indoor/outdoor pollution and irritants
- Other factors that can influence asthma severity:
  - Rhinitis/sinusitis
  - Gastroesophageal reflux
  - Sensitivity to aspirin, other nonsteroidal anti-inflammatory drugs, and sulfites
  - Topical and systemic beta-blockers
  - Viral respiratory infections

## Inhalant Allergens

Exposure of an asthma patient to inhalant allergens to which the patient is sensitive increases airway inflammation and symptoms. Substantially reducing such exposure will result in significantly reduced inflammation, symptoms, and need for medication (see a summary of the evidence in box 5-1). In the opinion of the Expert Panel, patients with asthma at any level of severity should be queried about exposures to inhalant allergens.

Box 5-1 The Strong Association between Sensitization to Allergies and Asthma: A Summary of the Evidence

The association of asthma and allergy has long been recognized. Recent studies confirm that sensitization among genetically susceptible populations to certain indoor allergens such as house-dust mite, animal dander, and cockroach or to the outdoor fungus Alternaria is a risk for developing asthma in children (Peat et al. 1993, 1994; Sears et al. 1993a, 1993b; Sporik et al. 1990). Sensitization to outdoor pollens carries less risk for asthma (Sears et al. 1989), although grass (Reid et al. 1986) and ragweed (Creticos et al. 1996) pollen exposure has been associated with seasonal asthma. It is widely accepted that the importance of inhalant sensitivity as a cause of asthma declines with advancing age (Pollart et al. 1989).

An allergic reaction in the airways caused by natural exposure to allergens has been shown to lead to an increase in inflammatory reaction, increased airway hyperresponsiveness (Boulet et al. 1983; Peroni et al. 1994; Piacentini et al. 1993), and increased eosinophils in bronchoalveolar lavage (Rak et al. 1991). Other research has demonstrated that asthma symptoms, pulmonary function, and need for medication in mite-sensitive asthma patients correlate with the level of house-dust mite exposure (Vervloet et al. 1991; Zock et al. 1994) and that reducing house-dust mite exposure reduces asthma symptoms, nonspecific bronchial hyperresponsiveness, and evidence of active inflammation (Peroni et al. 1994; Piacentini et al. 1993; Simon et al. 1994). Inhalant allergen exposure to seasonal outdoor fungal spores (Targonski et al. 1995; O'Hollaren et al. 1991) and to indoor allergens (Call et al. 1994) has also been implicated in fatal exacerbations of asthma. These reports emphasize that allergen exposure must be considered in the treatment of asthma.

The important allergens for children and adults appear to be those that are inhaled. Food allergens are not a common precipitant of asthma symptoms. Foods are an important cause of anaphylaxis in adults and children (Golbert et al. 1969; Sampson et al. 1992), but significant lower respiratory tract symptoms are uncommon even with positive double-blind food challenges (James et al. 1994).

### Diagnosis—Determine Relevant Inhalant Sensitivity

Demonstrating a patient's relevant sensitivity to inhalant allergens will enable the clinician to recommend specific environmental controls to reduce exposures. It will also help the patient understand the pathogenesis of asthma and the value of allergen avoidance. Given the importance of allergens and their control to asthma morbidity and asthma management, the Expert Panel recommends that patients with persistent asthma who require daily therapy be evaluated for allergens as possible contributing factors as follows:

1. Determine the patient's exposure to allergens (see relevant questions in box 5-2).
2. Assess sensitivity to the allergens to which the patient is exposed.
  - Use the patient's medical history, which is usually sufficient, to determine sensitivity to seasonal allergens.
  - Use skin testing or in vitro testing to determine the presence of specific IgE antibodies to the indoor allergens to which the patient is exposed year round (see box 5-3 for a comparison of skin and in vitro tests). Allergy testing is the only reliable way to determine sensitivity to perennial indoor allergens (see box 5-4 for further explanation).
    (For selected patients with asthma at any level of severity, detection of specific IgE sensitivity to seasonal or perennial allergens may be indicated as a basis for avoidance, for immunotherapy, or to characterize the patient's atopic status.)
3. Assess the clinical significance of positive allergy tests in the context of the patient's medical history (see box 5-5).

Box 5-2 Assessment Questions^*^ * These questions are examples and do not represent a standardized assessment or diagnostic instrument. The validity and reliability of these questions have not been assessed. for Environmental and Other Factors That Can Make Asthma Worse

##### Inhalant Allergens

Does the patient have symptoms year round? (If yes, ask the following questions. If no, see next set of questions.)

Does the patient keep pets indoors? What type?

Does the patient have moisture or dampness in any room of his or her home (e.g., basement)? (Suggests house-dust mites, molds.)

Does the patient have mold visible in any part of his or her home? (Suggests molds.)

Has the patient seen cockroaches in his or her home in the past month? (Suggests significant cockroach exposure.)

Assume exposure to house-dust mites unless patient lives in a semiarid region. However, if a patient living in a semiarid region uses a swamp cooler, exposure to house dust mites must still be assumed.

Do symptoms get worse at certain times of the year? (If yes, ask when symptoms occur.)

Early spring? (trees)

Late spring? (grasses)

Late summer to autumn? (weeds)

Summer and fall? (Alternaria, Cladosporium)

##### Tobacco Smoke

Does the patient smoke?

Does anyone smoke at home or work?

Does anyone smoke at the child's day care?

##### Indoor/Outdoor Pollutants and Irritants

Is a wood-burning stove or fireplace used in the patient's home?

Are there unvented stoves or heaters in the patient's home?

Does the patient have contact with other smells or fumes from perfumes, cleaning agents, or sprays?

##### Workplace Exposures

Does the patient cough or wheeze during the week, but not on weekends when away from work?

Do the patient's eyes and nasal passages get irritated soon after arriving at work?

Do coworkers have similar symptoms?

What substances are used in the patient's worksite? (Assess for sensitizers.)

##### Rhinitis

Does the patient have constant or seasonal nasal congestion and/or postnasal drip?

##### Gastroesophageal Reflux

Does the patient have heartburn?

Does food sometimes come up into the patient's throat?

Has the patient had coughing, wheezing, or shortness of breath at night in the past 4 weeks?

Does the infant vomit followed by cough or have wheezy cough at night? Are symptoms worse after feeding?

##### Sulfite Sensitivity

Does the patient have wheezing, coughing, or shortness of breath after eating shrimp, dried fruit, or processed potatoes or after drinking beer or wine?

##### Medication Sensitivities and Contraindications

What medications does the patient use now (prescription and nonprescription)?

Does the patient use eyedrops? What type?

Does the patient use any medications that contain beta-blockers?

Does the patient ever take aspirin or other nons-teroidal anti-inflammatory drugs?

Has the patient ever had symptoms of asthma after taking any of these medications?

Box 5-3 Comparison of Skin Tests with in Vitro Tests

##### Advantages of skin tests

Less expensive than in vitro tests

Results are available within 1 hour.

More sensitive than in vitro tests

Results are visible to the patient. This may encourage compliance with environmental control measures.

##### Advantages of RAST and other in vitro tests

Do not require knowledge of skin testing technique

Do not require availability of allergen extracts

Can be performed on patients who are taking medications that suppress the immediate skin test (antihistamines, antidepressants)

No risk of systemic reactions

Can be done for patients with extensive eczema

Box 5-4 Rationale for Allergy Testing for Perennial Indoor Allergens

Determination of sensitivity to a perennial indoor allergen is usually not possible with a patient medical history alone (Murray and Milner 1995). Increased symptoms during vacuuming or bed making and decreased symptoms when away from home on a business trip or vacation are suggestive but not sufficient. Allergy skin or in vitro tests are reliable in determining the presence of specific IgE (Adinoff et al. 1990), but these tests do not determine whether the specific IgE is responsible for the patient's symptoms. That is why patients should only be tested for sensitivity to the allergens to which they are exposed and why the third step in evaluating patients for allergen sensitivity calls for assessing the clinical relevance of the sensitivity.

The recommendation to do skin or in vitro tests for patients with persistent asthma exposed to perennial indoor allergens will result in a limited number of allergy tests for about half of all asthma patients. This is based on the prevalence of persistent asthma and the level of exposure to indoor allergens. It is estimated that about half of all asthma patients have persistent asthma based on data on children in the United States (Taylor and Newacheck 1992) and on adults in Australia (Boston Consulting Group 1992). About 80 percent of the U.S. population is exposed to house-dust mites (Nelson and Fernandez-Caldas 1995), 60 percent to cat or dog, and a much smaller percentage to both animals (Ingram et al. 1995). Cockroaches are a consideration only in the inner city and southern parts of the United States.

Skin or in vitro tests for patients exposed to perennial allergens are essential to justify the expense and effort involved in implementing environmental controls. In addition, patient adherence to maintaining environmental controls (e.g., with regard to pets) is likely to be poor without proof of the patient's sensitivity.

Box 5-5 Patient Interview Questions^*^ * These questions are provided as examples for the clinician. The validity and reliability of these questions have not been assessed. for Assessing the Clinical Significance of Positive Allergy Tests

Animal Dander. If there are pets in the patient's home and the patient is sensitive to dander of that species of animal, the likelihood that animal dander allergy is contributing to asthma symptoms is increased if answers to the following questions are affirmative. However, absence of positive responses does not exclude a contribution of animal dander to the patient's symptoms.

- Do nasal, eye, or chest symptoms appear in a room where carpets are being or have just been vacuumed?
- Do nasal, eye, or chest symptoms improve when away from home for a week or longer?
- Do the symptoms become worse the first 24 hours after returning home?

House-Dust Mites. Mite allergy is more likely to be a contributing factor to asthma severity if answers to the following questions are affirmative. However, absence of a positive response does not exclude a contribution of mite allergen to the patient's symptoms.

- Do nasal, eye, or chest symptoms appear in a room where carpets are being or have just been vacuumed?
- Does making a bed cause nasal, eye, or chest symptoms?

Outdoor Allergens (Pollens and Outdoor Molds). Contribution of pollens and outdoor molds in causing asthma symptoms is suggested by a positive answer to this question:

- Is asthma consistently worse in spring, summer, fall, or parts of the growing season?

Usually, if pollen or mold spores are causing increased asthma symptoms, the patient will also have symptoms of allergic rhinitis—sneezing, itching nose and eyes, runny and obstructed nose.

Indoor Fungi (Molds). Contribution of indoor molds in causing asthma symptoms is suggested by a positive answer to this question:

- Do nasal, eye, or chest symptoms appear in damp or moldy rooms, such as basements?

#### Management—Reduce Exposure

The first and most important step in controlling allergen-induced asthma is to reduce exposure to relevant indoor and outdoor allergens. Effective ways patients can reduce their exposures to indoor and outdoor allergens are discussed below and summarized in box 5-6, which also addresses irritants. Although these recommendations focus on the home environment, reductions in exposures to allergens and irritants are also appropriate in other environments where the patient spends extended periods of time, such as school, work, or day care. For information about companies that distribute products to help reduce allergen exposure, contact the Asthma and Allergy Foundation of America at 800-727-8462 or the Allergy and Asthma Network/Mothers of Asthmatics at 800-878-4403.

Box 5-6 Summary of Control Measures for Environmental Factors That Can Make Asthma Worse

###### Allergens

Reduce or eliminate exposure to the allergen(s) the patient is sensitive to, including:

Animal dander: Remove animal from house or, at a minimum, keep animal out of patient's bedroom and seal or cover with a filter air ducts that lead to bedroom.

House-dust mites:

- Essential: Encase mattress in an allergen-impermeable cover; encase pillow in an allergen-impermeable cover or wash it weekly; wash sheets and blankets on the patient's bed in hot water weekly (water temperature of ≥130 °F is necessary for killing mites).
- Desirable: Reduce indoor humidity to less than 50 percent; remove carpets from the bedroom; avoid sleeping or lying on upholstered furniture; remove carpets that are laid on concrete.

Cockroaches: Use poison bait or traps to control. Do not leave food or garbage exposed.

Pollens (from trees, grass, or weeds) and outdoor molds: To avoid exposures, adults should stay indoors with windows closed during the season in which they have problems with outdoor allergens, especially during the afternoon.

Indoor mold: Fix all leaks and eliminate water sources associated with mold growth; clean moldy surfaces. Consider reducing indoor humidity to less than 50 percent.

###### Tobacco Smoke

Advise patients and others in the home who smoke to stop smoking or to smoke outside the home. Discuss ways to reduce exposure to other sources of tobacco smoke, such as from day care providers and the workplace.

###### Indoor/Outdoor Pollutants and Irritants

Discuss ways to reduce exposures to the following:

Wood-burning stoves or fireplaces

Unvented stoves or heaters

Other irritants (e.g., perfumes, cleaning agents, sprays)

- Animal Allergens. All warm-blooded pets, including small rodents and birds, produce dander, urine, feces, and saliva that can cause allergic reactions (Swanson et al. 1985; de Blay et al. 1991a). No studies have been published on the effect of animal allergen avoidance on asthma symptoms; however, based on the opinion of the Expert Panel, the following actions to control animal antigens are recommended:
  - If the patient is sensitive, remove the animal and products made of feathers from the home to eliminate exposure.
  - If removal of the animal is not acceptable:
    - Keep the pet out of the patient's bedroom.
    - Keep the patient's bedroom door closed. Consider placing dense filtering material over forced air outlets to trap airborne dander particles.
    - Remove upholstered furniture and carpets from the home or isolate the pet from them to the extent possible.
  Weekly washing of the pet may decrease the amount of dander and dried saliva the animal contributes to the environment (de Blay et al. 1991b; Klucka et al. 1995).
- House-Dust Mite Allergen. House-dust mites are universal in areas of high humidity (most areas of the United States) but are usually not present at high altitudes or in arid areas unless moisture is added to the indoor air. Mites depend on atmospheric moisture and human dander for survival. High levels of mites can be found in dust from mattresses, pillows, carpets, upholstered furniture, bed covers, clothes, and soft toys. The patient's bed is the most important source of dust mites to control. Recommended mite control measures are listed below (Platts-Mills et al. 1982).
  Essential actions to control mites include:
  - Encase the mattress in an allergen-impermeable cover.
  - Encase the pillow in an allergen-impermeable cover or wash it weekly.
  - Wash the sheets and blankets on the patient's bed weekly in hot water. A temperature of ≥130 °F is necessary for killing house-dust mites.
  Desirable actions to control mites include:
  - Reduce indoor humidity to less than 50 percent.
  - Remove carpets from the bedroom.
  - Avoid sleeping or lying on upholstered furniture.
  - Remove from the home carpets that are laid on concrete.
  - In children's beds, minimize the number of stuffed toys and wash the toys weekly in hot water.
  Chemical agents are available for killing mites and denaturing the antigen; however, the effects are not dramatic and do not appear to be maintained for long periods. Therefore, use of these agents in the homes of house-dust mite-sensitive asthma patients should not be recommended routinely (Woodfolk et al. 1995). Vacuuming removes mite allergen from carpets but is inefficient at removing live mites.
- Cockroach Allergen. Cockroach sensitivity and exposure are common among patients with asthma who live in inner cities (Kang et al. 1993; Call et al. 1992). In an inner-city asthma study, asthma severity increased with increasing levels of cockroach antigen in the bedroom of sensitized children (Rosenstreich et al. 1997). Although no studies have been published that report the effect of cockroach reduction on asthma symptoms, it is the opinion of the Expert Panel that control measures need to be instituted when the patient is sensitive to cockroaches and infestation is present in the home. Patients should not leave food or garbage exposed. Poison baits, boric acid, and traps are preferred to chemical agents because the latter can be irritating when inhaled by asthma patients. If chemical agents are used, the home should be well ventilated and the patient should not return to the home until the odor has dissipated.
- Indoor Fungi (Molds). Indoor fungi are particularly prominent in humid environments and homes that have dampness problems. Children living in homes with dampness have increased respiratory symptoms (Cuijpers et al. 1995; Verhoeff et al. 1995), but the relative contribution of fungi, house-dust mites, or irritants is not clear. Because an association between indoor fungi and respiratory and allergic disease is suggested by some studies (Bjornsson et al. 1995; Smedje et al. 1996; Strachan 1988), measures to control dampness or fungal growth in the home may be beneficial.
- Outdoor Allergens (Tree, Grass, and Weed Pollens and Seasonal Mold Spores). Patients can reduce exposure by staying indoors with windows closed in an air-conditioned environment (Solomon et al. 1980), particularly during the midday and afternoon when pollen and some spore counts are highest (Long and Kramer 1972; Smith and Rooks 1954; Mullins et al. 1986). Conducting outdoor activities shortly after sunrise will result in less pollen exposure. These actions may not be realistic for some patients, especially children.

### Immunotherapy

Allergen immunotherapy may be considered for asthma patients when (1) there is clear evidence of a relationship between symptoms and exposure to an unavoidable allergen to which the patient is sensitive, (2) symptoms occur all year or during a major portion of the year, and (3) there is difficulty controlling symptoms with pharmacologic management either because the medication is ineffective, multiple medications are required, or the patient is not accepting of medication. This recommendation is based on the opinion of the Expert Panel and the evidence described below. If use of allergen immunotherapy is elected, it should be administered only in a physician's office where facilities and trained personnel are available to treat any life-threatening reaction that can, but rarely does, occur (AAAI Board of Directors 1994; Frew 1993). Controlled studies of immunotherapy, usually conducted with single allergens, have demonstrated reduction in asthma symptoms caused by exposure to grass, cat, house-dust mite, ragweed, Cladosporium, and Alternaria (Reid et al. 1986; Malling et al. 1986; Creticos et al. 1996; Horst et al. 1990). A meta-analysis of 20 randomized, placebo-controlled studies has confirmed the effectiveness of immunotherapy in asthma (Abramson et al. 1995). Few studies have been reported on multiple allergen mixes, which are commonly employed in clinical practice.

The course of allergen immunotherapy is typically of 3 to 5 years' duration. Reactions to immunotherapy, especially bronchoconstriction, are more frequent among patients with asthma, particularly those with poorly controlled asthma, compared with those with allergic rhinitis (Reid et al. 1993). For this reason, enthusiasm for the use of immunotherapy differs considerably among experts (Abramson et al. 1995; Canadian Society of Allergy and Clinical Immunology 1995; Frew 1993).

### Assessment of Devices That May Modify Indoor Air

- Vacuuming carpets once or twice a week is essential to reduce accumulation of house dust. Patients sensitive to components of house dust should avoid using conventional vacuum cleaners, and these patients should stay out of rooms where a vacuum cleaner is being or has just been used (Murray et al. 1983). If patients vacuum, they can use a dust mask, a central cleaner with the collecting bag outside the home, or a cleaner fitted with a HEPA (high-efficiency particulate air) filter or with a double bag (Woodfolk et al. 1993).
- Humidifiers and evaporative (swamp) coolers are not recommended for use in the homes of house-dust mite-sensitive patients with asthma. These are potentially harmful because increased humidity may encourage the growth of both mold (Solomon 1976) and house-dust mites (Ellingson et al. 1995). In addition, humidifiers may pose a problem if not properly cleaned because they can harbor and aerosolize mold spores (Solomon 1974).
- Air conditioning during warm weather is recommended for asthma patients because it allows windows and doors to stay closed, which prevents entry of outdoor allergens (Solomon et al. 1980). Regular use of central air conditioning also will usually control humidity sufficiently to reduce house-dust mite growth (Lintner and Brame 1993).
- Use of a dehumidifier will reduce house-dust mite levels in areas where the humidity of the outside air remains high for most of the year (Cabrera et al. 1995).
- Indoor air-cleaning devices cannot substitute for the more effective measures described previously (see page 43, Management—Reduce Exposure). However, air-cleaning devices (i.e., HEPA and electrostatic precipitating filters) have been shown to reduce airborne cat dander (de Blay et al. 1991b), mold spores (Maloney et al. 1987), and particulate tobacco smoke (U.S. Environmental Protection Agency 1990). Air cleaners cannot significantly reduce exposure to house-dust mite and cockroach allergens because these heavy particles do not remain airborne (de Blay et al. 1991a). Most studies of air cleaners have failed to demonstrate an effect on asthma symptoms or pulmonary function (Nelson et al. 1988; Reisman et al. 1990; Warner et al. 1993; Warburton et al. 1994).
- Air-duct cleaning of heating/ventilation/air conditioning systems has been reported to decrease levels of airborne fungi in residences (Garrison et al. 1993). The effect on levels of house-dust mite or animal dander has not been studied. Limited evidence precludes the Expert Panel from making a recommendation in this area.

## Occupational Exposures

Early recognition and control of exposures are particularly important in occupationally induced asthma, because the likelihood of complete resolution of symptoms decreases with time (Chan-Yeung et al. 1987; Pisati et al. 1993). Occupational asthma is suggested by a correlation between asthma symptoms and work, with improvement when away from work for several days. Other indications of workplace exposure are listed in box 5-7. The patient may fail to recognize the work relationship, because symptoms often begin several hours after exposure. Serial peak flow records at work and away from work can confirm the work association (Moscato et al. 1995).

Box 5-7 Evaluation and Management of Work-aggravated Asthma and Occupational Asthma

#### Evaluation

##### Potential for workplace-related symptoms

Recognized sensitizers (e.g., isocyanates, plant or animal products).

Irritants^*^ or physical stimuli (e.g., cold/heat, dust, humidity).

* Material Safety Data Sheets may be helpful for identifying respiratory irritants, but many sensitizers are not listed.

Coworkers may have similar symptoms.

##### Patterns of symptoms (in relation to work exposures)

Improvement during vacations or days off (may take a week or more).

Symptoms may be immediate (<1 hour), delayed (most commonly, 2 to 8 hours after exposure), or nocturnal.

Initial symptoms may occur after high-level exposure (e.g., spill).

##### Documentation of work-relatedness of airflow limitation

Serial charting for 2 to 3 weeks (2 weeks at work and up to 1 week off work as needed to identify or exclude work-related changes in peak expiratory flow):

- Record when symptoms and exposures occur.
- Record when a bronchodilator is used.
- Measure and record peak flow every 2 hours while awake.

Immunologic tests.

Referral for further confirmatory evaluation (e.g., bronchial challenges).

#### Management

##### Work-aggravated asthma

Work with onsite health care providers or managers/supervisors.

Discuss avoidance, ventilation, respiratory protection, tobacco smoke-free environment.

##### Occupationally induced asthma

Recommend complete cessation of exposure to initiating agent.

Workplace exposure to sensitizing chemicals or dusts can induce asthma, which often persists after the exposures are terminated (Chan-Yeung et al. 1987; Pisati et al. 1993). This should be distinguished from allergen- or irritant-induced aggravation of preexisting asthma. Acute exposure to irritant gases, dusts, or fumes can cause an asthma-like condition (reactive airway dysfunction syndrome) (Brooks et al. 1985).

Patient confidentiality issues are particularly important in work-related asthma. Because even general inquiries about the potential adverse health effects of work exposures may occasionally result in reprisals against the patient (e.g., job loss), asthma patients need to be informed of this possibility and be full partners in the decision to approach management regarding the effects or control of workplace exposures.

## Irritants

In the opinion of the Expert Panel, patients with asthma at any level of severity should be queried about exposures to irritants. Sample assessment questions are in box 5-2.

### Environmental Tobacco Smoke

Asthma patients should not smoke or be exposed to environmental tobacco smoke (Marquette et al. 1992). Tobacco smoke is the most important environmental indoor irritant and is a major precipitant of asthma symptoms in children and adults (Abbey et al. 1993; Greer et al. 1993; Jindal et al. 1994; Leuenberger et al. 1994). Jindal and colleagues (1994) found that exposure of adults to environmental tobacco smoke is associated with decreased levels of pulmonary function, increased requirements for medication, and more frequent absences from work. In addition, exposure to maternal smoke has been shown to be a risk factor for the development of asthma in infancy (Arshad and Hide 1992) and childhood (Frischer et al. 1992; Schmitzberger et al. 1993; Gortmaker et al. 1982; Henderson et al. 1995; Soyseth et al. 1995; Martinez et al. 1995; Agudo et al. 1994), although not for persistence of childhood asthma into adulthood (Roorda et al. 1993).

### Indoor/Outdoor Air Pollution and Irritants

Asthma patients should avoid exertion or exercise outside to the extent possible when levels of air pollution are high. Increased pollution levels, particularly of respirable particulates (Abbey et al. 1993; Koenig et al. 1993; Pope et al. 1991; Walters et al. 1994; Schwartz et al. 1993; Ostro et al. 1995) and ozone (Abbey et al. 1993; Cody et al. 1992; Ponka 1991; Thurston et al. 1992; Ostro et al. 1995; Romieu et al. 1995; Kesten et al. 1995; White et al. 1994), but also of SO_2_ (Moseholm et al. 1993) and NO_2_ (Moseholm et al. 1993; Kesten et al. 1995), have been reported to precipitate symptoms of asthma (Abbey et al. 1993; Koenig et al. 1987; Moseholm et al. 1993; Pope et al. 1991) and to increase emergency department visits and hospitalizations for asthma (Walters et al. 1994; Schwartz et al. 1993; Cody et al. 1992; Ponka 1991; Thurston et al. 1992; Romieu et al. 1995; Kesten et al. 1995; White et al. 1994).

Patients also should avoid exposure to fumes from unvented gas, oil, or kerosene stoves; wood-burning appliances or fireplaces (Ostro et al. 1994); sprays; and strong odors because they irritate the lungs and can precipitate asthma symptoms.

## Other Factors That Can Influence Asthma Severity

### Rhinitis/Sinusitis

Treatment of upper respiratory tract symptoms is an integral part of asthma management. Intranasal corticosteroids are recommended for the treatment of chronic rhinitis in patients with persistent asthma. Antihistamine/decongestant combinations also may be used; they provide symptomatic relief but have not been shown to have a protective effect on the lower airways secondary to their action on the nose. Intranasal corticosteroids reduce nasal inflammation, obstruction, and discharge and have been shown to reduce lower airway hyperresponsiveness and asthma symptoms (Aubier et al. 1992; Watson et al. 1993; Corren et al. 1992; Welsh et al. 1987). Intranasal cromolyn has been shown to reduce symptoms of asthma during the ragweed season, but to a lesser extent than intranasal corticosteroids in the same study (Welsh et al. 1987).

Treatment of sinusitis includes medical measures to promote drainage (Zeiger 1992) and the use of antibiotics when complicating acute bacterial infection is present (Wald 1992; Gwaltney et al. 1992). In cases of subacute or chronic sinusitis, physicians need to make a judgment regarding the appropriateness of antibiotic therapy. Antibiotic therapy was not shown to be of clear benefit in children who had nasal symptoms or cough for longer than 3 weeks and who had abnormal sinus x rays but no fever (Dohlman et al. 1993).

Asthma is commonly associated with perennial and seasonal rhinitis and sinusitis. Studies indicate that inflammation of the upper airway contributes to lower airway hyperresponsiveness and asthma symptoms (Watson et al. 1993; Corren et al. 1992; Welsh et al. 1987). The histopathology in the chronically thickened mucosa of the paranasal sinuses is similar to that in the nose and bronchi, with a primarily eosinophilic infiltrate that, in most patients, is notably lacking in neutrophils (Harlin et al. 1988; Demoly et al. 1994).

### Gastroesophageal Reflux

Medical management of gastroesophageal reflux should be instituted for any patients with asthma complaining of frequent heartburn or pyrosis, particularly those with frequent episodes of nocturnal asthma. Medical management of gastroesophageal reflux includes:

- Avoiding food and drink within 3 hours of retiring (Nelson 1984)
- Elevating the head of the bed on 6- to 8-inch blocks (Nelson 1984)
- Using appropriate pharmacologic therapy (Hixson et al. 1992)

For patients who have persistent symptoms following optimal therapy, further evaluation is indicated.

For patients with poorly controlled asthma, particularly with a nocturnal component, investigation for gastroesophageal reflux may be warranted even in the absence of suggestive symptoms (Irwin et al. 1989).

The symptoms of gastroesophageal reflux are common in both children and adults with asthma (Nelson 1984). Reflux during sleep can contribute to nocturnal asthma (Martin et al. 1982; Davis et al. 1983). Both medical (Ekstrom et al. 1989) and surgical (Perrin-Fayolle et al. 1989) therapy of gastroesophageal reflux have been reported to reduce the symptoms of asthma.

### Aspirin Sensitivity

Adult patients with asthma should be questioned regarding precipitation of bronchoconstriction by aspirin and other nonsteroidal anti-inflammatory drugs. If they have experienced a reaction to any of these drugs, they should be informed of the potential for all these drugs to precipitate severe and even fatal exacerbations. Adult patients with severe persistent asthma or nasal polyps should be counseled regarding the risk of using these drugs. Usually safe alternatives to aspirin include acetaminophen or salsalate (Szczeklik et al. 1977; Settipane et al. 1995).

From 3 percent of patients with asthma seen in a private allergy practice (Chafee and Settipane 1974) to 39 percent of adults with asthma admitted to an asthma referral hospital (Spector et al. 1979) have been reported to experience severe and even fatal exacerbations of asthma after taking aspirin or certain other nonsteroidal anti-inflammatory drugs. The prevalence of aspirin sensitivity increases with increasing age and severity of asthma (Chafee and Settipane 1974; Spector et al. 1979).

### Sulfite Sensitivity

Patients who have asthma symptoms associated with eating processed potatoes, shrimp, or dried fruit or with drinking beer or wine should avoid these products (Taylor et al. 1988). These products contain sulfites, which are used to preserve foods and beverages. They have caused severe asthma exacerbations, particularly in patients with severe persistent asthma.

### Beta-Blockers

Nonselective beta-blockers, including those in ophthalmological preparations, can cause asthma symptoms and should be avoided by asthma patients (Odeh et al. 1991; Schoene et al. 1984), although cardioselective beta-blockers, such as betaxolol, may be tolerated (Dunn et al. 1986).

### Infections

Annual influenza vaccinations are recommended for patients with persistent asthma (Bell et al. 1978; CDC 1993). It is well established that viral respiratory infections can exacerbate asthma, particularly in children with asthma under the age of 10 (Busse et al. 1993). Respiratory syncytial virus, rhinovirus, and influenza virus have been implicated (Busse et al. 1993), with rhinovirus being implicated in the majority of the exacerbations of asthma in children (Johnston et al. 1995). The role of infections causing exacerbations of asthma also appears to be important in adults (Nicholson et al. 1993).

Viral infections are the most frequent precipitants of asthma exacerbations in infancy. In the majority of cases, young children are predisposed to have bronchial obstruction during viral infections because of very small airway size (Martinez et al. 1995) and will not have further exacerbations after infancy. However, chronic asthma also may start as early as the first year of life among infants with a family history of asthma, persistent rhinorrhea, atopic dermatitis, or high IgE levels. Early identification of these infants allows institution of environmental controls to reduce exposure to tobacco smoke, animal dander, and house-dust mites.

## Preventing the Onset of Asthma

Primary prevention of asthma (preventing initial development) is an accepted approach for occupational asthma (Venables 1994; Chan-Yeung et al. 1987) but remains unproven outside the workplace. Recent studies indicate that exposures to high levels of house-dust mite antigen (Sporik et al. 1990; Peat et al. 1993, 1994) and environmental tobacco smoke (Martinez et al. 1995; Kuehr et al. 1995) are associated with an increased incidence of asthma among infants. This suggests that reducing these exposures may result in reduction in the incidence of asthma. Prolonged breast feeding and avoidance of early introduction of allergenic foods have been reported to reduce eczema and food sensitization but not to reduce the prevalence of asthma (Zeiger 1994).

## References

Adinoff A D, Rosloniec D M, McCall L L, Nelson H S. Immediate skin test reactivity to Food and Drug Administration-approved standardized extracts. J Allergy Clin Immunol. 1990;86:766-74. [pmid: 2229841].
American Academy of Allergy and Immunology Board of Directors. Guidelines to minimize the risk from systemic reactions caused by immunotherapy with allergenic extracts. J Allergy Clin Immunol. 1994;93:811-2. [pmid: 8163793].
Abbey D E, Petersen F, Mills P K, Beeson W L. Long-term ambient concentrations of total suspended particulates, ozone, and sulfur dioxide and respiratory symptoms in a nonsmoking population. Arch Environ Health. 1993;48:33-46. [pmid: 8452397].
Abramson M J, Puy R M, Weiner J M. Is allergen immunotherapy effective in asthma? A meta-analysis of randomized controlled trials. Am J Respir Crit Care Med. 1995;151:969-74. [pmid: 7697274].
Agudo A, Bardagí S, Romero P V, González C A. Exercise-induced airways narrowing and exposure to environmental tobacco smoke in schoolchildren. Am J Epidemiol. 1994;140:409-17. [pmid: 8067333].
Arshad S H, Hide D W. Effect of environmental factors on the development of allergic disorders in infancy. J Allergy Clin Immunol. 1992;90:235-41. [pmid: 1500628].
Aubier M, Levy J, Clerici C, Neukirch F, Herman D. Different effects of nasal and bronchial glucocorticosteroid administration on bronchial hyperresponsiveness in patients with allergic rhinitis. Am Rev Respir Dis. 1992;146:122-6. [pmid: 1626795].
Bell T D, Chai H, Berlow B, Daniels G. Immunization with killed influenza virus in children with chronic asthma. Chest. 1978;73:140-5. [pmid: 340157].
Bjornsson E, Norback D, Janson C, et al. Asthmatic symptoms and indoor levels of micro-organisms and house-dust mites. Clin Exp Allergy. 1995;25:423-31. [pmid: 7553245].
Boston Consulting Group. Report on the cost of asthma in Australia. New South Wales, Australia, National Asthma Campaign. 1992.
Boulet L P, Cartier A, Thomson N C, Roberts R S, Dolovich J, Hargreave F E. Asthma and increases in nonallergic bronchial responsiveness from seasonal pollen exposure. J Allergy Clin Immunol. 1983;71:399-406. [pmid: 6601124].
Brooks S M, Weiss M A, Bernstein I L. Reactive airways dysfunction syndrome (RADS). Persistent asthma syndrome after high level irritant exposures. Chest. 1985;88:376-84. [pmid: 4028848].
Busse WW, Lemanske RF Jr, Stark JM, Calhoun WJ. The role of respiratory infections in asthma. In: Holgate ST, Austen KF, Lichtenstein LM, Kay AB, eds. Asthma: Physiology, Immunopharmacology, and Treatment. London: Academic Press, 1993. Ch. 26, pp. 345–53.
Cabrera P, Julia-Serda G, Rodriguez de Castro F, Caminero J, Barber D, Carrillo T. Reduction of house dust mite allergens after dehumidifier use. J Allergy Clin Immunol. 1995;95:635-6. [pmid: 7852676].
Call R S, Smith T F, Morris E, Chapman M D, Platts-Mills T A E. Risk factors for asthma in inner city children. J Pediatr. 1992;121:862-6. [pmid: 1447646].
Call R S, Ward G, Jackson S, Platts-Mills T A E. Investigating severe and fatal asthma. J Allergy Clin Immunol. 1994;94:1065-72. [pmid: 7798539].
Canadian Society of Allergy and Clinical Immunology. Guidelines for the use of allergen immunotherapy. Can Med Assoc J. 1995;152:1413-9. [pmid: 7728690].
Centers for Disease Control and Prevention. Prevention and control of influenza. Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR 1993;42(No. RR-6):1–14.
Chafee F H, Settipane G A. Aspirin intolerance. I. Frequency in an allergic population. J Allergy Clin Immunol. 1974;53:193-9.
Chan-Yeung M, MacLean L, Paggiaro P L. Follow-up study of 232 patients with occupational asthma caused by western red cedar (Thuja plicata). J Allergy Clin Immunol. 1987;79:792-6. [pmid: 3571771].
Cody R P, Weisel C P, Birnbaum G, Lioy P J. The effect of ozone associated with summertime photochemical smog on the frequency of asthma visits to hospital emergency departments. Environ Res. 1992;58:184-94. [pmid: 1511672].
Corren J, Adinoff A D, Buchmeier A D, Irvin C G. Nasal beclomethasone prevents the seasonal increase in bronchial responsiveness in patients with allergic rhinitis and asthma. J Allergy Clin Immunol. 1992;90:250-6. [pmid: 1500629].
Creticos P S, Reed C E, Norman P S, et al. Ragweed immunotherapy in adult asthma. N Engl J Med. 1996;334(8):501-6. [pmid: 8559203].
Cuijpers C E, Swaen G M, Wesseling G, Sturmans F, Wouters E F. Adverse effects of the indoor environment on respiratory health in primary school children. Environ Res. 1995;68:11-23. [pmid: 7729382].
Davis R S, Larsen G L, Grunstein M M. Respiratory response to intraesophageal acid infusion in asthmatic children during sleep. J Allergy Clin Immunol. 1983;72:393-8. [pmid: 6619453].
de Blay F, Chapman M D, Platts-Mills T A E. Airborne cat allergen (Fel d I): environmental control with the cat in situ. Am Rev Respir Dis. 1991b;143:1334-9. [pmid: 2048821].
de Blay F, Heymann P W, Chapman M D, Platts-Mills T A E. Airborne dust mite allergens: comparison of group II allergens with group I mite allergen and cat-allergen Fel d I. J Allergy Clin Immunol. 1991a;88:919-26. [pmid: 1744363].
Demoly P, Crampette L, Mondain M, et al. Assessment of inflammation in noninfectious chronic maxillary sinusitis. J Allergy Clin Immunol. 1994;94:95-108. [pmid: 8027503].
Dohlman A W, Hemstreet M P, Odrezin G T, Bartolucci A A. Subacute sinusitis: are antimicrobials necessary?. J Allergy Clin Immunol. 1993;91:1015-23. [pmid: 8491934].
Dunn T L, Gerber M J, Shen A S, Fernandez E, Iseman M D, Cherniack R M. The effect of topical ophthalmic instillation of timolol and betaxolol on lung function in asthmatic subjects. Am Rev Respir Dis. 1986;133:264-8. [pmid: 3946922].
Ekstrom T, Lindgren B R, Tibbling L. Effects of ranitidine treatment on patients with asthma and a history of gastro-oesophageal reflux: a double-blind crossover study. Thorax. 1989;44:19-23. [pmid: 2648642].
Ellingson A R, LeDoux R A, Vedanthan P K, Weber R W. The prevalence of Dermatophagoides mite allergen in Colorado homes utilizing central evaporative coolers. J Allergy Clin Immunol. 1995;96:473-9. [pmid: 7560657].
Frew A J. Injection immunotherapy. British Society for Allergy and Clinical Immunology Working Party. BMJ. 1993;307:919-23. [pmid: 8241857].
Frischer T, Kuehr J, Meinert R, et al. Maternal smoking in early childhood: a risk factor for bronchial responsiveness to exercise in primary-school children. J Pediatr. 1992;121:17-22. [pmid: 1625083].
Garrison R A, Robertson L D, Koehn R D, Wynn S R. Effect of heating-ventilation-air conditioning system sanitation on airborne fungal populations in residential environments. Ann Allergy. 1993;71:548-56. [pmid: 8267249].
Golbert T M, Patterson R, Pruzansky J J. Systemic allergic reactions to ingested antigens. J Allergy. 1969;44:96-107. [pmid: 4184542].
Gortmaker S L, Walker D K, Jacobs F H, Ruch-Ross H. Parental smoking and the risk of childhood asthma. Am J Public Health. 1982;72:574-9. [pmid: 7072874].
Greer J R, Abbey D E, Burchette R J. Asthma related to occupational and ambient air pollutants in nonsmokers. J Occup Med. 1993;35:909-15. [pmid: 8229343].
Gwaltney J M Jr, Scheld W M, Sande M A, Sydnor A. The microbial etiology and antimicrobial therapy of adults with acute community-acquired sinusitis: a fifteen-year experience at the University of Virginia and review of other selected studies. J Allergy Clin Immunol. 1992;90:457-61. [pmid: 1527337].
Harlin S L, Ansel D G, Lane S R, Myers J, Kephart G M, Gleich G J. A clinical and pathologic study of chronic sinusitis: the role of the eosinophil. J Allergy Clin Immunol. 1988;81:867-75. [pmid: 3286721].
Henderson F W, Henry M M, Ivins S S, et al. Correlates of recurrent wheezing in school-age children. The physicians of Raleigh Pediatric Associates. Am J Respir Crit Care Med. 1995;151:1786-93. [pmid: 7767521].
Hixson L J, Kelly C L, Jones W N, Tuohy C D. Current trends in the pharmacotherapy for gastroesophageal reflux disease. Arch Intern Med. 1992;152:717-23. [pmid: 1558428].
Horst M, Hejjaoui A, Horst V, Michel F B, Bousquet J. Double-blind, placebo-controlled rush immunotherapy with a standardized Alternaria extract. J Allergy Clin Immunol. 1990;85:460-72. [pmid: 2406323].
Ingram J M, Sporik R, Rose G, Honsinger R, Chapman M D, Platts-Mills T A E. Quantitative assessment of exposure to dog (Can f 1) and cat (Fel d 1) allergens: relation to sensitization and asthma among children living in Los Alamos, New Mexico. J Allergy Clin Immunol. 1995;96:449-56. [pmid: 7560654].
Irwin R S, Zawacki J K, Curley F J, French C L, Hoffman P J. Chronic cough as the sole presenting manifestation of gastroesophageal reflux. Am Rev Respir Dis. 1989;140:1294-1300. [pmid: 2817591].
James J M, Bernhisel-Broadbent J, Sampson H A. Respiratory reactions provoked by double-blind food challenges in children. Am J Respir Crit Care Med. 1994;149:59-64. [pmid: 8111598].
Jindal S K, Gupta D, Singh A. Indices of morbidity and control of asthma in adult patients exposed to environmental tobacco smoke. Chest. 1994;106:746-9. [pmid: 8082352].
Johnston S L, Pattemore P K, Sanderson G, et al. Community study of role of viral infections in exacerbations of asthma in 9 to 11 year old children. BMJ. 1995;310:1225-9. [pmid: 7767192].
Kang B C, Johnson J, Veres-Thorner C. Atopic profile of inner-city asthma with a comparative analysis on the cockroach-sensitive and ragweed-sensitive subgroups. J Allergy Clin Immunol. 1993;92:802-11. [pmid: 8258614].
Kesten S, Szalai J, Dzyngel B. Air quality and the frequency of emergency room visits for asthma. Ann Allergy Asthma Immunol. 1995;74:269-73. [pmid: 7889385].
Klucka C V, Ownby D R, Green J, Zoratti E. Cat shedding of Fel d I is not reduced by washings, Allerpet-C spray, or acepromazine. J Allergy Clin Immunol. 1995;95:1164-71. [pmid: 7797784].
Koenig J Q, Covert D S, Marshall S G, Van Belle G, Pierson W E. The effects of ozone and nitrogen dioxide on pulmonary function in healthy and in asthmatic adolescents. Am Rev Respir Dis. 1987;136:1152-7. [pmid: 3674577].
Koenig J Q, Larson T V, Hanley Q S, et al. Pulmonary function changes in children associated with fine particulate matter. Environ Res. 1993;63:26-38. [pmid: 8404772].
Kuehr J, Frischer T, Meinert R, et al. Sensitization to mite allergens is a risk factor for early and late onset of asthma and for persistence of asthmatic signs in children. J Allergy Clin Immunol. 1995;95(3):655-62. [pmid: 7897146].
Leuenberger P, Schwartz J, Ackermann-Liebrich U, et al. Passive smoking exposure in adults and chronic respiratory symptoms (SAPALDIA Study). Swiss Study on Air Pollution and Lung Diseases in Adults, SAPALDIA Team. Am J Respir Crit Care Med. 1994;150:1221-8.
Lintner T J, Brame K A. The effects of season, climate, and air conditioning on the prevalence of Dermatophagoides mite allergens in household dust. J Allergy Clin Immunol. 1993;91:862-7. [pmid: 8473674].
Long D L, Kramer C L. Air spora of two contrasting ecological sites in Kansas. J Allergy Clin Immunol. 1972;49:255-66. [pmid: 5019944].
Malling H J, Dreborg S, Weeke B. Diagnosis and immunotherapy of mould allergy. V. Clinical efficacy and side effects of immunotherapy with Cladosporium herbarum. Allergy. 1986;41:507-19. [pmid: 3789332].
Maloney M J, Wray B B, DuRant R H, Smith L, Smith L. Effect of an electronic air cleaner and negative ionizer on the population of indoor mold spores. Ann Allergy. 1987;59:192-4. [pmid: 3631655].
Marquette C H, Saulnier F, Leroy O, et al. Long-term prognosis of near-fatal asthma. A 6-year follow-up study of 145 asthmatic patients who underwent mechanical ventilation for a near-fatal attack of asthma. Am Rev Respir Dis. 1992;146:76-81. [pmid: 1626819].
Martin M E, Grunstein M M, Larsen G L. The relationship of gastroesophageal reflux to nocturnal wheezing in children with asthma. Ann Allergy. 1982;49:318-22. [pmid: 6890782].
Martinez F D, Wright A L, Taussig L M, Holberg C J, Halonen M, Morgan W J. Asthma and wheezing in the first six years of life. The Group Health Medical Associates. N Engl J Med. 1995;332:133-8. [pmid: 7800004].
Moscato G, Godnic-Cvar J, Maestrelli P. Statement on self-monitoring of peak expiratory flows in the investigation of occupational asthma. Subcommittee on Occupational Allergy of European Academy of Allergy and Clinical Immunology. J Allergy Clin Immunol. 1995;96:295-301. [pmid: 7560631].
Moseholm L, Taudorf E, Frosig A. Pulmonary function changes in asthmatics associated with low-level SO_2_ and NO_2_ air pollution, weather, and medicine intake. An 8-month prospective study analyzed by neural networks. Allergy. 1993;48:334-44. [pmid: 8368460].
Mullins J, White J, Davies B H. Circadian periodicity of grass pollen. Ann Allergy. 1986;57:371-4. [pmid: 3777538].
Murray A B, Milner R A. The accuracy of features in the clinical history for predicting atopic sensitization to airborne allergens in children. J Allergy Clin Immunol. 1995;96:588-96. [pmid: 7499674].
Murray A B, Ferguson A C, Morrison B J. Diagnosis of house dust mite allergy in asthmatic children: what constitutes a positive history?. J Allergy Clin Immunol. 1983;71:21-8. [pmid: 6822690].
Nelson H S. Gastroesophageal reflux and pulmonary disease. J Allergy Clin Immunol. 1984;73:547-56. [pmid: 6371102].
Nelson H S, Fernandez-Caldas E. Prevalence of house-dust mites in the Rocky Mountain States. Ann Allergy Asthma Immunol. 1995;75:337-9. [pmid: 7583849].
Nelson H S, Hirsch S R, Ohman J L Jr, Platts-Mills T A E, Reed C E, Solomon W R. Recommendations for the use of residential air-cleaning devices in the treatment of allergic respiratory diseases. J Allergy Clin Immunol. 1988;82:661-9. [pmid: 3171006].
Nicholson K G, Kent J, Ireland D C. Respiratory viruses and exacerbations of asthma in adults. BMJ. 1993;307:982-6. [pmid: 8241910].
Odeh M, Oliven A, Bassan H. Timolol eyedrop-induced fatalbronchospasm in an asthmatic patient. J Fam Pract. 1991;32:97-8. [pmid: 1985142].
O'Hollaren M T, Yunginger J W, Offord K P, et al. Exposure to an aeroallergen as a possible precipitating factor in respiratory arrest in young patients with asthma. N Engl J Med. 1991;324:359-63. [pmid: 1987459].
Ostro B D, Lipsett M J, Mann J K, Braxton-Owens H, White M C. Air pollution and asthma exacerbations among African-American children in Los Angeles. Inhal Toxicol. 1995;7:711-22.
Ostro B D, Lipsett M J, Mann J K, Wiener M B, Selner J. Indoor air pollution and asthma. Results from a panel study. Am J Respir Crit Care Med. 1994;149:1400-6. [pmid: 8004290].
Peat J K, Tovey E, Gray E J, Mellis C M, Woolcock A J. Asthma severity and morbidity in a population sample of Sydney schoolchildren: part II—importance of house dust mite allergens. Aust N Z J Med. 1994;24:270-6. [pmid: 7980209].
Peat J K, Tovey E, Mellis C M, Leeder S R, Woolcock A J. Importance of house dust mite and Alternaria allergens in childhood asthma: an epidemiological study in two climatic regions of Australia. Clin Exp Allergy. 1993;23:812-20. [pmid: 10780887].
Peroni D G, Boner A L, Vallone G, Antolini I, Warner J O. Effective allergen avoidance at high altitude reduces allergen-induced bronchial hyperresponsiveness. Am J Respir Crit Care Med. 1994;149:1442-6. [pmid: 8004296].
Perrin-Fayolle M, Gormand F, Braillon G, et al. Long-term results of surgical treatment for gastroesophageal reflux in asthmatic patients. Chest. 1989;96:40-5. [pmid: 2736991].
Piacentini G L, Martinati L, Fornari A, et al. Antigen avoidance in a mountain environment: influence on basophil releasability in children with allergic asthma. J Allergy Clin Immunol. 1993;92(5):644-50. [pmid: 7693784].
Pisati G, Baruffini A, Zedda S. Toluene diisocyanate induced asthma: outcome according to persistence or cessation of exposure. Br J Ind Med. 1993;50:60-4. [pmid: 8381658].
Platts-Mills T A E, Tovey E R, Mitchell E B, et al. Reduction of bronchial hyperreactivity during prolonged allergen avoidance. Lancet. 1982;2:675-8. [pmid: 6126624].
Pollart S M, Chapman M D, Fiocco G P, Rose G, Platts-Mills T A E. Epidemiology of acute asthma: IgE antibodies to common inhalant allergens as a risk factor for emergency room visits. J Allergy Clin Immunol. 1989;83:875-82. [pmid: 2715548].
Ponka A. Asthma and low level air pollution in Helsinki. Arch Environ Health. 1991;46:262-70. [pmid: 1953033].
Pope C A, Dockery D W, Spengler J D, Raizenne M E. Respiratory health and PM10 pollution. A daily time series analysis. Am Rev Respir Dis. 1991;144:668-74. [pmid: 1892309].
Rak S, Bjornson A, Hakanson L, Sorenson S, Venge P. The effect of immunotherapy on eosinophil accumulation and production of eosinophil chemotatic activity in the lung of subjects with asthma during natural pollen exposure. J Allergy Clin Immunol. 1991;88:878-88. [pmid: 1744358].
Reid M J, Lockey R F, Turkeltaub P C, Platts-Mills T A E. Survey of fatalities from skin testing and immunotherapy 1985-1989. J Allergy Clin Immunol. 1993;92:6-15. [pmid: 8335856].
Reid M J, Moss R B, Hsu Y P, Kwasnicki J M, Commerford T M, Nelson B L. Seasonal asthma in northern California: allergic causes and efficacy of immunotherapy. J Allergy Clin Immunol. 1986;78:590-600. [pmid: 3771951].
Reisman R E, Mauriello P M, Davis G B, Georgitis J W, DeMasi J M. A double-blind study of the effectiveness of a high-efficiency particulate air (HEPA) filter in the treatment of patients with perennial allergic rhinitis and asthma. J Allergy Clin Immunol. 1990;85:1050-7. [pmid: 2191991].
Romieu I, Meneses F, Sienra-Monge J J, et al. Effects of urban air pollutants on emergency visits for childhood asthma in Mexico City. Am J Epidemiol. 1995;141:546-53. [pmid: 7900722].
Roorda R J, Gerritsen J, Van Aalderen W M, et al. Risk factors for the persistence of respiratory symptoms in childhood asthma. Am Rev Respir Dis. 1993;148:1490-5. [pmid: 8256889].
Rosenstreich, Eggleston P, Kattan M, et al. for the National Cooperative Inner-City Asthma Study. The role of cockroach allergy and exposure to cockroach allergen in causing morbidity among inner-city children with asthma. N Engl J Med. 1997;336:1356-63. [pmid: 9134876].
Sampson H A, Mendelson L, Rosen J P. Fatal and near-fatal anaphylactic reactions to food in children and adolescents. N Engl J Med. 1992;327:380-4. [pmid: 1294076].
Schmitzberger R, Rhomberg K, Buchele H, et al. Effects of air pollution on the respiratory tract of children. Pediatr Pulmunol. 1993;15:68-74.
Schoene R B, Abuan T, Ward R L, Beasley C H. Effects of topicalbetaxolol, timolol, and placebo on pulmonary function in asthmatic bronchitis. Am J Ophthalmol. 1984;97:86-92. [pmid: 6141730].
Schwartz J, Slater D, Larson T V, Pierson W E, Koenig J Q. Particulate air pollution and hospital emergency room visits for asthma in Seattle. Am Rev Respir Dis. 1993;147:826-31. [pmid: 8466116].
Sears M R, Burrows B, Flannery E M, Herbison G P, Holdaway M D. Atopy in childhood. I. Gender and allergen related risks for development of hay fever and asthma. Clin Exp Allergy. 1993b;23:941-8. [pmid: 10779282].
Sears M R, Burrows B, Herbison G P, Holdaway M D, Flannery E M. Atopy in childhood. II. Relationship to airway responsiveness, hay fever, and asthma. Clin Exp Allergy. 1993a;23:949-56. [pmid: 10779283].
Sears M R, Herbison G P, Holdaway M D, Hewitt C J, Flannery E M, Silva P A. The relative risks of sensitivity to grass pollen, house dust mite, and cat dander in the development of childhood asthma. Clin Exp Allergy. 1989;19:419-24. [pmid: 2758355].
Settipane R A, Schrank P J, Simon R A, Mathison D A, Christiansen S C, Stevenson D D. Prevalence of cross-sensitivity with acetaminophen in aspirin-sensitive asthmatic subjects. J Allergy Clin Immunol. 1995;96:480-5. [pmid: 7560658].
Simon H U, Grotzer M, Nikolaizik W H, Blaser K, Schoni M H. High altitude climate therapy reduces peripheral blood T lymphocyte activation, eosinophilia, and bronchial obstruction in children with house-dust mite allergic asthma. Pediatr Pulmonol. 1994;17:304-11. [pmid: 8058424].
Smith R D, Rooks R. The diurnal variation of air-borne ragweed pollen as determined by a continuous recording particle sampler and implications of the study. J Allergy. 1954;25:36-45. [pmid: 13117610].
Smedje G, Norbäck D, Wessén B, Edling C. Asthma among school employees in relation to the school environment. Indoor Air 96, the 7th International Conference on Indoor Air Quality and Climate, July 21-6, 1996, Nagoya, Japan. Proceedings; vol. 1:611–6.
Solomon W R. Fungus aerosols arising from cold-mist vaporizers. J Allergy Clin Immunol. 1974;54:222-8. [pmid: 4413523].
Solomon W R. A volumetric study of winter fungus prevalence in the air of midwestern homes. J Allergy Clin Immunol. 1976;57:46-55. [pmid: 942733].
Solomon W R, Burge H A, Boise J R. Exclusion of particulate allergens by window air conditioners. J Allergy Clin Immunol. 1980;65:305-8. [pmid: 7358946].
Soyseth V, Kongerud J, Boe J. Postnatal maternal smoking increases the prevalence of asthma but not of bronchial hyperresponsiveness or atopy in their children. Chest. 1995;107:389-94. [pmid: 7842766].
Spector S L, Wangaard C H, Farr R S. Aspirin and concomitant idiosyncrasies in adult asthmatic patients. J Allergy Clin Immunol. 1979;64:500-6. [pmid: 512268].
Sporik R, Holgate S T, Platts-Mills T A E, Cogswell J J. Exposure to house-dust mite allergen (Der p I) and the development of asthma in childhood. A prospective study. N Engl J Med. 1990;323:502-7. [pmid: 2377175].
Strachan D P. Damp housing and childhood asthma: validation of reporting of symptoms. BMJ. 1988;297:1223-6. [pmid: 3145060].
Swanson M C, Agarwal M K, Reed C E. An immunochemical approach to indoor aeroallergen quantitation with a new volumetric air sampler: studies with mite, roach, cat, mouse and guinea pig antigens. J Allergy Clin Immunol. 1985;76:724-9. [pmid: 4056257].
Szczeklik A, Gryglewski R J, Czerniawska-Mysik G. Clinical patterns of hypersensitivity to nonsteroidal anti-inflammatory drugs and their pathogenesis. J Allergy Clin Immunol. 1977;60:276-84. [pmid: 410857].
Targonski P V, Persky V W, Ramekrishnan V. Effect of environmental molds on risk of death from asthma during the pollen season. J Allergy Clin Immunol. 1995;95:955-61. [pmid: 7751516].
Taylor S L, Bush R K, Selner J C, et al. Sensitivity to sulfited foods among sulfite-sensitive subjects with asthma. J Allergy Clin Immunol. 1988;81:1159-67. [pmid: 3379229].
Taylor W R, Newacheck P W. Impact of childhood asthma on health. Pediatrics. 1992;90:657-62. [pmid: 1408534].
Thurston G D, Ito K, Kinney P L, Lippmann M. A multi-year study of air pollution and respiratory hospital admissions in three New York State metropolitan areas: results for 1988 and 1989 summers. J Expo Anal Environ Epidemiol. 1992;2:429-50. [pmid: 1336418].
U.S. Environmental Protection Agency. Residential Air-Cleaning Devices: A Summary of Available Information. Washington, DC: Office of Air and Radiation, U.S. Environmental Protection Agency, 1990.
Venables K M. Prevention of occupational asthma. Eur Respir J. 1994;7:768-78. [pmid: 8005261].
Verhoeff A P, van Strien R T, van Wijnen J H, Brunekreef B. Damp housing and childhood respiratory symptoms: the role of sensitization to dust mites and molds. Am J Epidemio. 1995;141:103-10.
Vervloet D, Charpin D, Haddi E, et al. Medication requirements and house dust mite exposure in mite-sensitive asthmatics. Allergy. 1991;46:554-8. [pmid: 1796781].
Wald E R. Microbiology of acute and chronic sinusitis in children. J Allergy Clin Immunol. 1992;90:452-6. [pmid: 1527336].
Walters S, Griffiths R K, Ayres J G. Temporal association between hospital admissions for asthma in Birmingham and ambient levels of sulphur dioxide and smoke. Thorax. 1994;49:133-40. [pmid: 8128402].
Warburton C J, Niven R M, Pickering C A, Fletcher A M, Hepworth J, Francis H C. Domiciliary air filtration units, symptoms and lung function in atopic asthmatics. Respir Med. 1994;88(10):771-6. [pmid: 7846339].
Warner J A, Marchant J L, Warner J O. Double blind trial of ionisers in children with asthma sensitive to the house dust mite. Thorax. 1993;48:330-3. [pmid: 8511730].
Watson W T, Becker A B, Simons F E. Treatment of allergic rhinitis with intranasal corticosteroids in patients with mild asthma; effect on lower airway responsiveness. J Allergy Clin Immunol. 1993;91:97-101. [pmid: 8423275].
Welsh P W, Stricker W E, Chu C P, et al. Efficacy of beclomethasone nasal solution, flunisolide, and cromolyn in relieving symptoms of ragweed allergy. Mayo Clin Proc. 1987;62:125-34. [pmid: 3100877].
White M C, Etzel R A, Wilcox W D, Lloyd C. Exacerbations of childhood asthma and ozone pollution in Atlanta. Environ Res. 1994;65(1):56-68. [pmid: 8162885].
Woodfolk J A, Hayden M L, Couture N, Platts-Mills T A E. Chemical treatment of carpets to reduce allergen: comparison of the effects of tannic acid and other treatments on proteins derived from dust mites and cats. J Allergy Clin Immunol. 1995;96:325-33. [pmid: 7560634].
Woodfolk J A, Luczynska C M, de Blay F, Chapman M D, Platts-Mills T A E. The effect of vacuum cleaners on the concentration and particle size distribution of airborne cat allergen. J Allergy Clin Immunol. 1993;91:829-37. [pmid: 8473670].
Zeiger R S. Dietary manipulations in infants and their mothers and the natural course of atopic disease. Pediatr Allergy Immunol. 1994;5:33-43. [pmid: 7728227].
Zeiger R S. Prospects for ancillary treatment of sinusitis in the1990s. J Allergy Clin Immunol. 1992;90:478-95. [pmid: 1382084].
Zock J P, Brunekreef B, Hazebroek-Kampschreur A A, Roosjen C W. House dust mite allergen in bedroom floor dust and respiratory health of children with asthmatic symptoms. Eur Respir J. 1994;7:1254-9. [pmid: 7925903].