# Periodic Assessment and Monitoring: Essential for Asthma Management

Key Points
- The goals of therapy are to:
  - Prevent chronic and troublesome symptoms (e.g., coughing or breathlessness in the night, in the early morning, or after exertion)
  - Maintain (near) “normal” pulmonary function
  - Maintain normal activity levels (including exercise and other physical activity)
  - Prevent recurrent exacerbations of asthma and minimize the need for emergency department visits or hospitalizations
  - Provide optimal pharmacotherapy with least amount of adverse effects
  - Meet patients' and families' expectations of and satisfaction with asthma care
- Periodic assessments and ongoing monitoring of asthma are recommended to determine if the goals of therapy are being met. Measurements of the following are recommended:
  - Signs and symptoms of asthma
  - Pulmonary function
  - Quality of life/functional status
  - History of asthma exacerbations
  - Pharmacotherapy
  - Patient-provider communication and patient satisfaction
- Clinician assessment and patient self-assessment are the primary methods for monitoring asthma. Population-based assessment is beginning to be used by managed care organizations.
- Spirometry tests are recommended (1) at the time of initial assessment, (2) after treatment is initiated and symptoms and PEF have stabilized, and (3) at least every 1 to 2 years.
- Patients should be given a written action plan based on signs and symptoms and/or PEF; this is especially important for patients with moderate-to-severe persistent asthma or a history of severe exacerbations.
- Patients should be trained to recognize symptom patterns indicating inadequate asthma control and the need for additional therapy.
- Recommendations on how and when to do peak flow monitoring are presented.

Differences from 1991 Expert Panel Report
- The new report includes an additional goal of therapy (meet patients' and families' expectations of and satisfaction with asthma care) that was not listed in the 1991 report.
- Periodic assessment of six domains of patient health that correspond with the goals of asthma therapy are now recommended, including signs and symptoms, pulmonary function, quality of life, history of exacerbations, pharmacotherapy, and patient-provider communication and patient satisfaction.
- The following changes affecting peak flow monitoring have been made:
  - The recommendation for peak flow monitoring was changed from twice daily to morning. If the morning reading is less than 80 percent of personal best PEF, more frequent peak flow monitoring may be desired.
  - Discussion of inconsistencies in measurement among peak flow meters was added.
  - Use of the individual patient's personal best PEF is emphasized strongly.
- The recommendation for patients at all severity levels to monitor symptoms to recognize early signs of deterioration is emphasized.
- Sample questions to use in periodic assessments were added.

## Goals of Therapy

The purpose of periodic assessment and ongoing monitoring is to determine whether the goals of asthma therapy are being achieved. The goals of therapy are as follows:

- Prevent chronic and troublesome symptoms (e.g., coughing or breathlessness in the night, in the early morning, or after exertion)
- Maintain (near) “normal” pulmonary function
- Maintain normal activity levels (including exercise and other physical activity)
- Prevent recurrent exacerbations of asthma and minimize the need for emergency department visits or hospitalizations
- Provide optimal pharmacotherapy with minimal or no adverse effects
- Meet patients' and families' expectations of and satisfaction with asthma care

## Assessment Measures

The Expert Panel recommends ongoing monitoring in the six areas listed below to determine whether the goals of therapy are being met. The assessment measures for monitoring these six areas are described in this section and are recommended based on the opinion of the Expert Panel.

- Monitoring signs and symptoms of asthma
- Monitoring pulmonary function
  - Spirometry
  - Peak flow monitoring
- Monitoring quality of life/functional status
- Monitoring history of asthma exacerbations
- Monitoring pharmacotherapy
- Monitoring patient-provider communication and patient satisfaction

### Monitoring Signs and Symptoms of Asthma

Every patient with asthma should be taught to recognize symptom patterns that indicate inadequate asthma control (see Patient Self-Assessment section, page 38, and component 4). Symptom monitoring should be used as a means to determine the need for intervention, including additional medication, in the context of an action plan (see figure 9-4).

Symptoms and clinical signs of asthma should be assessed at each health care visit through physical examination and appropriate questions. This is crucial to optimal asthma care. A description of the important elements of an asthma-related physical examination can be found in component 1-Initial Assessment and Diagnosis, which also discusses the variability in the types of symptoms associated with asthma.

Detailed patient recall of symptoms decreases over time; therefore, the Expert Panel recommends that any detailed symptoms history be based on a short (2 to 4 weeks) recall period. For example, the clinician may choose to assess over a 2-week, 3-week, or 4-week recall period. Symptom assessment for periods longer than 4 weeks should reflect more global symptom assessment, such as inquiring whether the patient's asthma has been better or worse since the last visit and inquiring whether the patient has encountered any particular difficulties during specific seasons or events. Box 4-1 provides an example of a set of questions that can be used to characterize both global (long-term recall) and recent (short-term recall) asthma symptoms.

Box 4-1 Components of the Clinician's Followup Assessment: Sample Routine Clinical Assessment Questions^*^ * These questions are examples and do not represent a standardized assessment instrument. The validity and reliability of these questions have not been assessed.

##### Monitoring Signs and Symptoms

(Global assessment) “Has your asthma been better or worse since your last visit?”

(Recent assessment) “In the past 2 weeks, how many days have you:

- Had problems with coughing, wheezing, shortness of breath, or chest tightness during the day?”
- Awakened at night from sleep because of coughing or other asthma symptoms?”
- Awakened in the morning with asthma symptoms that did not improve within 15 minutes of inhaling a shortacting inhaled beta_2_-agonist?”
- Had symptoms while exercising or playing?”

##### Monitoring Pulmonary Function

###### Lung Function

“What is the highest and lowest your peak flow has been since your last visit?”

“Has your peak flow dropped below ___ L/min (80 percent of personal best) since your last visit?”

“What did you do when this occurred?”

###### Peak Flow Monitoring Technique

“Please show me how you measure your peak flow.”

“When do you usually measure your peak flow?”

##### Monitoring Quality of Life/Functional Status

“Since your last visit, how many days has your asthma caused you to:

- Miss work or school?”
- Reduce your activities?”
- (For caregivers) Change your activity because of your child's asthma?”

“Since your last visit, have you had any unscheduled or emergency department visits or hospital stays?”

##### Monitoring Exacerbation History

“Since your last visit, have you had any episodes/times when your asthma symptoms were a lot worse than usual?”

If yes - “What do you think caused the symptoms to get worse?”

If yes - “What did you do to control the symptoms?”

“Have there been any changes in your home or work environment (e.g., new smokers or pets)?”

##### Monitoring Pharmacotherapy

###### Medications

“What medications are you taking?”

“How often do you take each medication?”

“How much do you take each time?”

“Have you missed or stopped taking any regular doses of your medications for any reason?”

“Have you had trouble filling your prescriptions (e.g., for financial reasons, not on formulary)?”

“How many puffs of your short-acting inhaled beta_2_-agonist (quick-relief medicine) do you use per day?”

“How many [name short-acting inhaled beta_2_-agonist] inhalers [or pumps] have you been through in the past month?”

“Have you tried any other medicines or remedies?”

###### Side Effects

“Has your asthma medicine caused you any problems?”

- Shakiness, nervousness, bad taste, sore throat, cough, upset stomach

###### Inhaler Technique

“Please show me how you use your inhaler.”

##### Monitoring Patient-Provider Communication and Patient Satisfaction

“What questions have you had about your asthma daily self-management plan and action plan?”

“What problems have you had following your daily self-management plan? Your action plan?”

“Has anything prevented you from getting the treatment you need for your asthma from me or anyone else?”

“Have the costs of your asthma treatment interfered with your ability to get asthma care?”

“How satisfied are you with your asthma care?”

“How can we improve your asthma care?”

“Let's review some important information:”

- “When should you increase your medications? Which medication(s)?”
- “When should you call me [your doctor or nurse practitioner]? Do you know the after-hours phone number?”
- “If you can't reach me, what emergency department would you go to?”

In addition, any assessment of the patient's symptom history should include at least three key symptom expressions:

- Daytime asthma symptoms (including wheezing, cough, chest tightness, or shortness of breath)
- Nocturnal awakening as a result of asthma symptoms
- Asthma symptoms early in the morning that are not improved 15 minutes after inhaling a short-acting beta_2_-agonist

### Monitoring Pulmonary Function

In addition to assessing symptoms, it is also important to periodically assess pulmonary function. The main methods are spirometry and peak flow monitoring.

Regular monitoring of pulmonary function is particularly important for asthma patients who do not perceive their symptoms until airflow obstruction is severe. Currently, there is no readily available method of detecting the “poor perceivers.” The literature reports that patients who had a near-fatal asthma exacerbation, as well as older patients, are more likely to have poor perception of airflow obstruction (Kikuchi et al. 1994; Connolly et al. 1992).

#### Spirometry

The Expert Panel recommends that spirometry tests be done (1) at the time of initial assessment; (2) after treatment is initiated and symptoms and peak expiratory flow (PEF) have stabilized, to document attainment of (near) “normal” airway function; and (3) at least every 1 to 2 years to assess the maintenance of airway function.

Spirometry may be indicated more often than every 1 to 2 years, depending on the clinical severity and response to management. Spirometry with measurement of the FEV_1_ is also useful:

- As a periodic (e.g., yearly) check on the accuracy of the peak flow meter (Miles et al. 1995)
- When more precision is desired in measuring lung function (e.g., when evaluating response to bronchodilator or nonspecific airway responsiveness or when assessing response to a “step down” in pharmacotherapy)
- When PEF results are unreliable (e.g., in some very young or elderly patients or when neuromuscular or orthopedic problems are present) and the physician needs the quality checks that are available only with spirometry (Hankinson and Wagner 1993).

For routine monitoring at most outpatient visits, measurement of PEF with a peak flow meter is generally a sufficient assessment of pulmonary function, particularly in mild intermittent, mild persistent, and moderate persistent asthma.

#### Peak Flow Monitoring

Peak expiratory flow provides a simple, quantitative, and reproducible measure of the existence and severity of airflow obstruction. PEF can be measured with inexpensive and portable peak flow meters. It must be stressed that peak flow meters are designed as tools for ongoing [underlined: monitoring], not [underlined: diagnosis.] Because the measurement of PEF is dependent on effort and technique, patients need instructions, demonstrations, and frequent reviews of technique (see box 4-2, the patient handout How To Use Your Peak Flow Meter).

Box 4-2 How To Use Your Peak Flow Meter

A peak flow meter is a device that measures how well air moves out of your lungs. During an asthma episode, the airways of the lungs usually begin to narrow slowly. The peak flow meter may tell you if there is narrowing in the airways hours—sometimes even days—before you have any asthma symptoms.

By taking your medicine(s) early (before symptoms), you may be able to stop the episode quickly and avoid a severe asthma episode. Peak flow meters are used to check your asthma the way that blood pressure cuffs are used to check high blood pressure.

The peak flow meter also can be used to help you and your doctor:

- Learn what makes your asthma worse
- Decide if your treatment plan is working well
- Decide when to add or stop medicine
- Decide when to seek emergency care

A peak flow meter is most helpful for patients who must take asthma medicine daily. Patients age 5 and older are usually able to use a peak flow meter. Ask your doctor or nurse to show you how to use a peak flow meter.

###### How To Use Your Peak Flow Meter

- Do the following five steps with your peak flow meter:
  1. Move the indicator to the bottom of the numbered scale.
  2. Stand up.
  3. Take a deep breath, filling your lungs completely.
  4. Place the mouthpiece in your mouth and close your lips around it. Do not put your tongue inside the hole.
  5. Blow out as hard and fast as you can in a single blow.
- Write down the number you get. But if you cough or make a mistake, don't write down the number. Do it over again.
- Repeat steps 1 through 5 two more times and write down the best of the three blows in your asthma diary.

###### Find Your Personal Best Peak Flow Number

Your personal best peak flow number is the highest peak flow number you can achieve over a 2- to 3-week period when your asthma is under good control. Good control is when you feel good and do not have any asthma symptoms.

Each patient's asthma is different, and your best peak flow may be higher or lower than the peak flow of someone of your same height, weight, and sex. This means that it is important for you to find your own personal best peak flow number. Your treatment plan needs to be based on your own personal best peak flow number.

To find out your personal best peak flow number, take peak flow readings:

- At least twice a day for 2 to 3 weeks.
- Between noon and 2:00 p.m. each day.
- [underlined: After] you take your short-acting inhaled beta_2_-agonist for quick relief, if you take this medicine.
- As instructed by your doctor.

###### The Peak Flow Zone System

Once you know your personal best peak flow number, your doctor will give you the numbers that tell you what to do. The peak flow numbers are put into zones that are set up like a traffic light. This will help you know what to do when your peak flow number changes. For example:

Green Zone (more than ___ L/min [80 percent of your personal best number]) signals good control. No asthma symptoms are present. Take your medicines as usual.

Yellow Zone (between ___ L/min and ___ L/min [50 to less than 80 percent of your personal best number]) signals caution. You must take a short-acting inhaled beta_2_-agonist right away. Also, your asthma may not be under good day-to-day control. Ask your doctor if you need to change or increase your daily medicines.

Red Zone (below ___ L/min [50 percent of your personal best number]) signals a medical alert. You must take a short-acting inhaled beta_2_-agonist (quick-relief medicine) right away. Call your doctor or emergency room and ask what to do, or go directly to the hospital emergency room.

Record your personal best peak flow number and peak flow zones in your asthma diary.

###### Use the Diary To Keep Track of Your Peak Flow

Measure your peak flow when you wake up, before taking medicine. Write down your peak flow number in the diary every day, or as instructed by your doctor.

###### Actions To Take When Peak Flow Numbers Change

- PEF goes between ___L/min and ___L/min (50 to less than 80 percent of personal best, yellow zone).
  ACTION: Take a short-acting inhaled beta_2_- agonist (quick-relief medicine) as prescribed by your doctor.
- PEF increases 20 percent or more when measured before and after taking a short-acting inhaled beta_2_-agonist (quick-relief medicine).
  ACTION: Talk to your doctor about adding more medicine to control your asthma better (for example, an anti-inflammatory medication).

Peak flow monitoring can be used for short-term monitoring, managing exacerbations, and daily long-term monitoring. When used in these ways, the patient's measured personal best is the most appropriate reference value. Four studies (Woolcock et al. 1988; Ignacio-Garcia and Gonzalez-Santos 1995; Lahdensuo et al. 1996; Beasley et al. 1989) have found that comprehensive asthma self-management programs, in which peak flow monitoring was a component, achieved significant improvements in health outcomes. Thus far, the few studies that have isolated a comparison of peak flow and symptom monitoring have not been sufficient to assess the relative contributions of each to asthma management (see box 4-3, Peak Flow Monitoring Literature Review). The literature does suggest which patients may benefit most from peak flow monitoring. The Expert Panel concludes, on the basis of this literature and the Panel's opinion, that:

Box 4-3 Peak Flow Monitoring Literature Review

Seven intervention studies on the use of daily peak flow monitoring for asthma management were identified, six through a MEDLINE search from 1980 to 1995 and reviews of reference lists and one from the 1996 literature.

Three randomized controlled trials (Woolcock et al. 1988, N=24; Ignacio-Garcia and Gonzalez-Santos 1995, N=70; Lahdensuo et al. 1996, N=115) and an uncontrolled pretest/posttest study (Beasley et al. 1989, N=36) tested comprehensive asthma interventions that included self-management medication plans, medications, education, and peak flow monitoring. These studies reported significant improvements in lung function, symptoms, and medication use after 6 months (Beasley et al. 1989; Ignacio-Garcia and Gonzalez-Santos 1995) and 18 months (Woolcock et al. 1988). However, these studies could not determine the relative importance of peak flow monitoring to the effectiveness of the comprehensive asthma intervention.

Three randomized controlled trials compared the use of daily peak flow monitoring with symptom monitoring (Charlton et al. 1990, N=115 adults and children) or usual care (Grampian Asthma Study 1994, N=569 adults; Jones et al. 1995, N=72 adults). These studies found no significant differences between the experimental and control groups in the outcomes measured: lung function, symptom frequency, quality of life, hospitalizations, medication use, and medical consultations. However, one of these studies involved patients with mild asthma (Jones et al. 1995), a population not expected to benefit as much from peak flow monitoring.

Almost all the peak flow monitoring studies available had study design and execution problems (e.g., selection bias, unequal control and experimental groups, small sample sizes, high loss to followup). More studies of daily long-term peak flow monitoring among patients with moderate and severe persistent asthma are urgently needed. Nonetheless, some issues suggested by the few studies available warrant consideration:

- Among patients with mild intermittent or mild persistent asthma, there appears to be no significant advantage of peak flow monitoring over usual care without peak flow monitoring (Jones et al. 1995).
- Patients with moderate-to-severe persistent asthma or unstable asthma are more likely to benefit from long-term daily peak flow monitoring. For example, the Grampian study authors conducted an observational study of 89 patients disqualified from the original study because their asthma was too severe and found that those who used peak flow meters took oral corticosteroids more often (action plan told patients to take oral corticosteroids at specific PEF levels) and had significantly fewer days of limited activity than those who did not use a peak flow meter.
- Short-term daily peak flow monitoring is helpful for assessing the severity of a patient's asthma and evaluating response to chronic maintenance therapy.
- Short-term peak flow monitoring is also helpful during exacerbations for assessing the severity of acute airflow obstruction and evaluating the patient's response to bronchodilator therapy. Janson-Bjerklie and Shnell (1988) found that patients used medications less frequently when they monitored PEF during symptomatic periods.
- Additional studies are needed to clarify the role of long-term daily peak flow monitoring in detecting early signs of deterioration, especially for patients with moderate-to-severe persistent asthma. Studies have found that 15 percent of asthma patients (Rubinfeld and Pain 1976), 24 to 27 percent of elderly patients (Connolly et al. 1992), and patients who had near-fatal asthma exacerbations (Kikuchi et al. 1994) could not perceive significant reductions in FEV_1_ provoked by methacholine challenge. A recent study in a general community setting found that for 60 percent of patients, their PEF did not correlate with the perception of how well their asthma was controlled (i.e., patients felt their asthma was better than the PEF readings indicated) (Kendrick et al. 1993). However, symptom monitoring and peak flow monitoring were found to be equally effective in identifying exacerbations that were confirmed by FEV_1_ measurements in a randomized controlled, crossover study (Malo et al. 1993). Although peak flow monitoring for children may be helpful, one study points out that the variability of individual PEF measurements between different brands of peak flow meters and in comparison to spirometry warrants caution about teaching how to use peak flow meters and interpret the measurements. Emphasis should be placed on observing differences between readings over time rather than on a single reading (Sly et al. 1994).
- Patient preferences regarding peak flow monitoring vary. One study found that most patients felt that peak flow monitoring was helpful (Jones et al. 1995), another found that most patients felt symptom monitoring was helpful (Garrett et al. 1994), and another study found that most patients felt that both forms of monitoring combined were helpful (D'souza et al. 1994). In an observational study of children attending a community clinic, 70 percent of the parents of children using peak flow monitoring reported it to be very useful, especially for judging the severity of an exacerbation and the child's response to inhaled short-acting beta_2_-agonist (Lloyd and Ali 1992).
- Linking peak flow monitoring to specific asthma management plans and providing appropriate instruction and feedback to the patient will influence the effectiveness and perceived usefulness of peak flow monitoring.

Due to the limited number and quality of the studies on peak flow monitoring reported thus far, the Expert Panel believes that more research is urgently needed in this area. Recent studies do offer some guidance on which patients are most likely to benefit from daily peak flow monitoring; see text of the report for recommendations.

- Patients with moderate-to-severe persistent asthma should learn how to monitor their PEF and have a peak flow meter at home.
- Peak flow monitoring during exacerbations of asthma is recommended for patients with moderate-to-severe persistent asthma to:
  - Determine severity of the exacerbation
  - Guide therapeutic decisions (see component 3-Managing Exacerbations and figure 9-4) in the home, clinician's office, or emergency department
- Long-term daily peak flow monitoring is helpful in managing patients with moderateto-severe persistent asthma to:
  - Detect early changes in disease status that require treatment
  - Evaluate responses to changes in therapy
  - Provide assessment of severity for patients with poor perception of airflow obstruction
  - Afford a quantitative measure of impairment
- If long-term daily peak flow monitoring is not used, a short-term (2 to 3 weeks) period of peak flow monitoring is recommended to:
  - Evaluate responses to changes in chronic maintenance therapy
  - Identify temporal relationship between changes in PEF and exposure to environmental or occupational irritants or allergens. It may be necessary to record PEF four or more times a day (Chan-Yeung 1995).
  - Establish the individual patient's personal best PEF
- The Expert Panel does not recommend long-term daily peak flow monitoring for patients with mild intermittent or mild persistent asthma unless the patient/family and/or clinician find it useful in guiding therapeutic decisions. Any patient who develops severe exacerbations may benefit from peak flow monitoring.

Limitations of long-term peak flow monitoring include:

- Difficulty in maintaining adherence to monitoring ( Reeder et al. 1990; Chmelik and Doughty 1994; Malo et al. 1993), often due to inconvenience, lack of required level of motivation, or lack of a specific treatment plan based on PEF
- Potential for incorrect readings related to poor technique, misinterpretation, or device failure Whether peak flow monitoring, symptom monitoring, or a combination of approaches is used, the Expert Panel believes that self-monitoring is important to the effective self-management of asthma. The nature and intensity of self-monitoring should be individualized, based on such factors as asthma severity, patient's ability to perceive airflow obstruction, availability of peak flow meters, and patient preferences.

It is the opinion of the Expert Panel that, regardless of the type of monitoring used, patients should be given a written action plan and be instructed to use it (see figure 9-4). The Panel believes it is especially important to give a written action plan to patients with moderate-to-severe persistent asthma and any patient with a history of severe exacerbations. The action plan will describe the actions patients should take based on their signs and symptoms and/or PEF. The clinician should periodically review the plan, revise it as necessary, and confirm that the patient knows what to do if his or her asthma gets worse.

Recommendations on How To Monitor Peak Flow. The Expert Panel recommends that patients who are using a peak flow meter be instructed on how to establish their personal best peak expiratory flow (box 4-2) and use it as the basis of their action plan (figure 9-4). Meters used to measure PEF should meet American Thoracic Society recommendations for monitoring devices (American Thoracic Society 1995).

The patient's personal best PEF can be estimated after a 2- to 3-week period in which the patient records PEF two to four times per day. The personal best value is usually achieved in the early afternoon measurement after maximal therapy has stabilized the patient (Quackenboss et al. 1991). A course of oral corticosteroids may be needed to establish the personal best PEF. The patient's personal best value should be reassessed periodically to account for progression of disease in children and adults and for growth in children. Occasionally, a PEF value is recorded that is markedly higher than other values. This may be due to “spitting” (especially if the peak flow meter mouthpiece is small) or coughing into the peak flow meter, as well as other reasons that are not well understood. Therefore, caution should be used in establishing a personal best value when an outlying value is observed. Children with moderate-to-severe persistent asthma should repeat the short-term monitoring period every 6 months to establish changes in personal best PEF that occur with growth.

Patients requiring daily peak flow monitoring should measure their PEF on waking from sleep in the morning before taking a bronchodilator, if the patient uses a bronchodilator (Reddel et al. 1995; Morris et al. 1994). When the morning PEF is below 80 percent of the patient's personal best, PEF should be measured more than once a day (again, before taking a bronchodilator). This recommendation is based not on scientific data, but on the logic of reducing delays in treatment. The additional measurements of PEF during the day will enable patients to detect if their asthma is continuing to worsen or is improving after taking medication. If their asthma is worsening, they will have the opportunity to quickly respond to this. In addition, periodically having patients take their PEF first thing in the morning and in the early afternoon for 1 to 2 weeks will assess airflow variability, which is an indicator of the current level of the patient's asthma severity (see table 3-1 and Additional Studies section, page 19).

It is the Expert Panel's opinion that, in general, PEF below 80 percent of the patient's personal best before bronchodilator inhalation indicates a need for additional medication. PEF below 50 percent indicates a severe asthma exacerbation (see component 3 for recommended treatment). These cutpoints of 80 and 50 percent of the personal best are somewhat arbitrary. The emphasis is not on a specific PEF value but, rather, on a patient's change from personal best or from one reading to the next. Cutpoints should be tailored to individual patients' needs and PEF patterns.

Cutpoints may be easier to use and remember when they are adapted to a traffic light system (see figure 9-4) (Lewis et al. 1984; Mendoza et al. 1988; Plaut 1995). In this system, for example, the green zone (80 to 100 percent of personal best) signals good control, the yellow zone (50 to less than 80 percent of personal best) signals caution, and the red zone (below 50 percent of personal best) signals a medical alert (see box 4-2). Because the yellow zone includes a wide spectrum of asthma severity, clinicians may consider recommending different interventions for a high yellow zone (e.g., 65 to less than 80 percent of personal best) and a low yellow zone (e.g., 50 to less than 65 percent of personal best).

The Expert Panel recommends that patients use the same peak flow meter over time and bring their peak flow meter for use at every followup visit. Using the same brand of meter is recommended because different brands of meters can give significantly different values (Jackson 1995; Enright et al. 1995; Hegewald et al. 1995; Sly et al. 1994; Miller et al. 1992) and because lung function varies across racial and ethnic populations. (See box 4-4, Differences in Peak Flow Across Racial and Ethnic Populations.) Thus, there is no universal normative standard for PEF. In addition, brand-specific normative values are not available for most peak flow meters.

Box 4-4 Differences in Peak Flow Across Racial and Ethnic Populations

Currently available normative standards for PEF use standing height as well as age and sex as predictors. However, for a given height, African Americans have longer legs, shorter trunks, and smaller thoracic diameters (Woolcock et al. 1972; Coultas et al. 1994). The normal ranges of lung function in Hispanics, Asians, and Native Americans have received less attention (Coultas et al. 1994). Differences have been reported among Caucasians and Japanese Americans (Marcus et al. 1988; Coultas et al. 1994), Native Americans (Wall et al. 1982; Crapo et al. 1988; Marcus et al. 1988), and Latinos (Hsu et al. 1979; Coultas et al. 1988, 1994). But these results are inconsistent, especially for Hispanics and Native Americans (Coultas et al. 1994). In general, lung function for these groups tends to be intermediate between those of Caucasians and African Americans.

Because predicted normal lung function varies across racial and ethnic populations, it is the opinion of the Expert Panel that (1) normative standards for PEF derived from a given racial or ethnic group cannot be readily extrapolated to other groups and that (2) the most clinically useful standard for ongoing monitoring of asthma is the patient's personal best PEF value.

Despite this variability across different brands of peak flow meters, measurements from the same meter and meters of the same brand are fairly consistent in measuring PEF (Jackson 1995; Enright et al. 1995; Hegewald et al. 1995; Sly et al. 1994; Miller et al. 1992). Thus, once patients establish their personal best PEF on their own meter, they can obtain reliable and clinically meaningful readings of their PEF. However, at each visit, the patient's peak flow meter should be inspected. At least once a year, or any time there is a question about the validity of peak flow meter readings, PEF values from the portable peak flow meter and from laboratory spirometry should be compared.

When patients replace their peak flow meter, it is prudent to have them reestablish their personal best PEF with the new meter, regardless of whether the replacement meter is the same brand as the original. Action plan cutpoints also may need to be modified. The durability and consistency over time of peak flow meters have not been adequately studied to provide guidance on when a peak flow meter needs to be replaced.

### Monitoring Quality of Life/Functional Status

To determine whether the goals of asthma therapy are being met, it is crucial to examine how the disease expression and control are affecting the patient's quality of life. Several dimensions of quality of life may be important to track, including physical function, role function, and mental health function. Several comprehensive survey instruments, such as the SF-36 (Stewart et al. 1988 for adult measure; Landgraf et al. 1996 for child measure), have been developed for general use for patient populations. In addition, a number of asthma-specific quality-of-life survey instruments have been developed (Creer et al. 1989; Hyland et al. 1991; Juniper et al. 1992; Marks et al. 1993; Richards and Hemstreet 1994), several of which appear promising. However, certain concerns preclude the Expert Panel from recommending the general adoption of these instruments at this time, such as the lack of experience with the use of the instruments in clinical practice and the time involved in administering the surveys. The Expert Panel does recommend that at least several key areas of quality of life be periodically assessed for each person with asthma. These include:

- Any missed work or school due to asthma
- Any reduction in usual activities (either home/work/school or recreation/exercise)
- Any disturbances in sleep due to asthma
- Any change in caregiver activities due to a child's asthma (for caregivers of children with asthma)

box 4-1 provides a set of questions that the Expert Panel recommends for use in characterizing quality-of-life concerns for persons with asthma (also see table 9-1).

### Monitoring History of Asthma Exacerbations

Exacerbations of asthma are characterized by periods of increased symptoms and reduced lung function, which may result in diminished ability to perform usual activities. Exacerbations may be brought on by exposures to irritants or sensitizers in the home, work, or general environment. Infections, certain medications, and a number of other medical conditions, as well as insufficient or ineffective therapy, also may trigger exacerbations (see component 2).

During periodic assessments, clinicians should question the patient and evaluate any records of patient self-monitoring (figures 4-1 and 4-2) to detect exacerbations, both self-treated and those treated by other health care providers. It is important to evaluate the frequency, severity, and causes of exacerbations. The patient should be asked about precipitating exposures and other factors. Specific inquiry into unscheduled visits to providers, telephone calls for assistance, and use of urgent or emergency care facilities may be helpful. Severity can be estimated by the increased need for oral corticosteroids. Control of asthma can be assessed by the increased need for short-acting beta_2_-agonist. Finally, any hospitalizations should be documented, including the facility, duration of stay, and any use of critical care or intubation. The clinician then can request summaries of all care received to facilitate continuity of care.

Figure 4-1 Sample* Patient Self-Assessment Sheet for Followup Visits

Figure 4-2 Patient Self-Assessment: Example of Patient Diary

### Monitoring Pharmacotherapy

To ensure the effectiveness of pharmacotherapy, it is essential that the drug regimen be based on a sound rationale and that it be monitored on an ongoing basis. Based on the opinion of the Expert Panel, the following factors should be monitored: patient adherence to the regimen, inhaler technique, level of usage of as-needed inhaled short-acting beta_2_-agonist, frequency of oral corticosteroid “burst” therapy, changes in dosage of inhaled anti-inflammatory or other longterm-control medications, and side effects of medications (see assessment questions in box 4-1). It is also critical that the clinician determine that the patient is on the appropriate step of pharmacotherapy (see component 3-Managing Asthma Long Term) and has an up-to-date, written daily self-management plan and action plan (see figures 9-2, 9-3 and 9-4).

### Monitoring Patient-Provider Communication and Patient Satisfaction

Health care providers should routinely assess the effectiveness of patient/provider communication (see box 4-1). Open and unrestricted communication among the clinician, the patient, and the family is essential to ensure successful self-management by the patient with asthma. Every effort should be made to encourage open discussion of concerns and expectation of therapy. See component 4 for specific strategies to enhance communication and patient adherence to the treatment plan.

Patient satisfaction with their asthma care and resolution of fears and concerns are important goals and will increase adherence to the treatment plan (Haynes et al. 1979; Meichenbaum and Turk 1987). Two aspects of patient satisfaction should be monitored: satisfaction with asthma control and satisfaction with the quality of care. See box 4-1, figure 4-1, and table 9-1 for examples of questions to use in monitoring patient satisfaction.

## Assessment Methods

Each of the key measures used in the periodic assessment of asthma (i.e., signs and symptoms, pulmonary function, quality of life, history of exacerbations, pharmacotherapy, and patient-provider communication and patient satisfaction) can be obtained by several methods. The principal methods include clinician assessment and patient (and/or parent or caregiver) self-assessment. In addition, population-based assessment of asthma care is being developed in the managed care field.

### Clinician Assessment

Clinical assessment of asthma should be obtained via medical history and physical examination with appropriate pulmonary function testing. Optimal history assessment may be best achieved via a consistent set of questions (box 4-1); physical examination for asthma is reviewed in component 1-Initial Assessment and Diagnosis. Patients with mild intermittent or mild persistent asthma that has been under control for at least 3 months should be seen by a clinician about every 6 months. This is a rough guideline based on the opinion of the Expert Panel. The exact frequency of clinician visits is a matter of clinical judgment. Patients with uncontrolled and/or severe persistent asthma and those needing additional supervision to help them follow their treatment plan need to be seen more often.

### Patient Self-Assessment

Self-assessment by the patient and/or family is important to determine from their perspective whether the asthma is well controlled. Two methods are recommended: a daily diary (see figure 4-2 for an example) and a periodic self-assessment form to be filled out by the patient and/or family member at the time of the followup visits to the clinician (figure 4-1).

- The daily diary should include the key factors to be monitored at home: symptoms and/or peak flow, medication use, and restricted activity.
- The periodic self-assessment sheet completed at office visits is intended to capture the patient's and family's impression of asthma control, self-management skills, and overall satisfaction with care.

Patients are less likely to see completion of diaries and forms as a burden if they receive feedback from the clinician that allows them to see value in selfmonitoring. Monitoring with a daily diary will be most useful to patients whose asthma is not yet under control and who are trying new treatments. It is also useful for those who need help identifying environmental or occupational exposures that make their asthma worse.

### Population-Based Assessment

Asthma care is of increasing interest in various health care settings. Important regulatory organizations for the industry (e.g., the National Committee on Quality Assurance) have included the care of persons with asthma as a key indicator of quality of managed care. In this context, periodic population-based assessment of asthma care has begun to emerge as an issue for patients and their clinical providers. This type of assessment often uses population experience, such as hospitalization or emergency department visit rates, to examine care within different clinical settings and among different providers. Complex standardized population surveys (including lengthy health status instruments) are being tested experimentally in the managed care setting.

## References

American Thoracic Society. Standardization of spirometry: 1994 update. Am J Respir Crit Care Med. 1995;152:1107-36. [pmid: 7663792].
Beasley R, Cushley M, Holgate S T. A self-management plan in the treatment of adult asthma. Thorax. 1989;44:200-4. [pmid: 2705150].
Chan-Yeung M. Assessment of asthma in the workplace. American College of Chest Physicians Consensus Statement. Chest. 1995;108:1084-117. [pmid: 7555124].
Charlton I, Charlton G, Broomfield J, Mullee M A. Evaluation of peak flow and symptoms only self-management plans for control of asthma in general practice. BMJ. 1990;301:1355-9. [pmid: 2148702].
Chmelik F, Doughty A. Objective measurements of compliance in asthma treatment. Ann Allergy. 1994;73:527-32. [pmid: 7998669].
Connolly M J, Crowley J J, Charan N B, Nielson C P, Vestal R E. Reduced subjective awareness of bronchoconstriction provoked by methacholine in elderly asthmatic and normal subjects as measured on a simple awareness scale. Thorax. 1992;47:410-3. [pmid: 1496497].
Coultas D B, Howard C A, Skipper B J, Samet J M. Spirometric prediction equations for Hispanic children and adults in New Mexico. Am Rev Respir Dis. 1988;138:1386-92. [pmid: 3202492].
Coultas D B, Gong H Jr, Grad R, et al. Respiratory diseases in minorities of the United States. Am J Respir Crit Care Med. 1994;149:S93-S131. [pmid: 8118656].
Crapo R O, Lockey J, Aldrich V, Jensen R L, Elliott C G. Normal spirometric values in healthy American Indians. J Occup Med. 1988;30:556-60. [pmid: 3397781].
Creer T L, Kotses H, Reynolds R V. Living with asthma. Part II. Beyond CARIH. J Asthma. 1989;26:31-52. [pmid: 2702214].
D'souza W, Crane J, Burgess C, et al. Community-based asthma care: trial of a “credit card” asthma self- management plan. Eur Respir J. 1994;7:1260-5. [pmid: 7925904].
Enright P L, Sherrill D L, Lebowitz M D. Ambulatory monitoring of peak expiratory flow. Reproducibility and quality control. Chest. 1995;107:657-61. [pmid: 7874933].
Garrett J, Fenwick J M, Taylor G, Mitchell E, Rea H. Peak expiratory flow meters (PEFMs)—who uses them and how does education affect the pattern of utilisation?. Aust N Z J Med. 1994;24:521-9. [pmid: 7848156].
Grampian Asthma Study of Integrated Care. Effectiveness of routine self-monitoring of peak flow in patients with asthma. BMJ. 1994;308:564-7. [pmid: 8148679].
Hankinson J L, Wagner G R. Medical screening using periodic spirometry for detection of chronic lung disease. Occup Med. 1993;8:353-61. [pmid: 8506511].
Haynes RB, Taylor DW, Sackett DL, eds. Compliance in Health Care. Baltimore: Johns Hopkins University Press, 1979.
Hegewald M J, Crapo R O, Jensen R L. Intraindividual peak flow variability. Chest. 1995;107:156-61. [pmid: 7813268].
Hsu K H, Jenkins D E, Hsi B P, et al. Ventilatory functions of normal children and young adults—Mexican American, white, and black. I. Spirometry. J Pediatr. 1979;95:14-23. [pmid: 479997].
Hyland M E, Finnis S, Irvine S H. A scale for assessing quality of life in adult asthma sufferers. J Psychosom Res. 1991;35:99-110. [pmid: 2023146].
Ignacio-Garcia J M, Gonzalez-Santos P. Asthma self-management education program by home monitoring of peak expiratory flow. Am J Respir Crit Care Med. 1995;151:353-9. [pmid: 7842191].
Jackson A C. Accuracy, reproducibility, and variability of portable peak flow meters. Chest. 1995;107:648-51. [pmid: 7874931].
Janson-Bjerklie S, Shnell S. Effect of peak flow information on patterns of self-care in adult asthma. Heart Lung. 1988;17:543-9. [pmid: 3417465].
Jones K P, Mullee M A, Middleton M, Chapman E, Holgate S T. Peak flow based asthma self-management: a randomised controlled study in general practice. British Thoracic Society Research Committee. Thorax. 1995;50:851-7. [pmid: 7570436].
Juniper E F, Guyatt G H, Epstein R S, Ferrie P J, Jaeschke R, Hiller T K. Evaluation of impairment of health related quality of life in asthma: development of a questionnaire for use in clinical trials. Thorax. 1992;47:76-83. [pmid: 1549827].
Kendrick A H, Higgs C M, Whitfield M J, Laszlo G. Accuracy of perception of severity of asthma: patients treated in general practice. BMJ. 1993;307:422-4. [pmid: 8374455].
Kikuchi Y, Okabe S, Tamura G, et al. Chemosensitivity and perception of dyspnea in patients with a history of near-fatal asthma. N Engl J Med. 1994;330:1329-34. [pmid: 8152444].
Lahdensuo A, Haahtela T, Herrala J, et al. Randomised comparison of guided self management and traditional treatment of asthma over one year. BMJ. 1996;312:748-52. [pmid: 8605463].
Landgraf JM, Abetz L, Ware JE. The CHQ User's Manual. First edition. Boston, MA: The Health Institute, New England Medical Center, 1996.
Lewis C E, Rachelefsky G, Lewis M A, de la Sota A, Kaplan M. A randomized trial of A.C.T. (Asthma Care Training) for kids. Pediatrics. 1984;74:478-86. [pmid: 6384911].
Lloyd B W, Ali M H. How useful do parents find home peak flow monitoring for children with asthma?. BMJ. 1992;305:1128-9. [pmid: 1463948].
Malo J L, L'Archeveque J, Trudeau C, d'Aquino C, Cartier A. Should we monitor peak expiratory flow rates or record symptoms with a simple diary in the management of asthma?. J Allergy Clin Immunol. 1993;91:702-9. [pmid: 8454792].
Marcus E B, MacLean C J, Curb J D, Johnson L R, Vollmer W M, Buist A S. Reference values for FEV_1_ in Japanese-American men from 45 to 68 years of age. Am Rev Respir Dis. 1988;138:1393-7. [pmid: 3202493].
Marks G B, Dunn S M, Woolcock A J. An evaluation of an asthma quality of life questionnaire as a measure of change in adults with asthma. J Clin Epidemiol. 1993;46:1103-11. [pmid: 8410095].
Meichenbaum D, Turk DC. Facilitating Treatment Adherence: A Practitioner's Guidebook. New York: Plenum Press, 1987.
Mendoza GR, Sander N, Scherrer D. A User's Guide to Peak Flow Monitoring. Mothers of Asthmatics, Inc., 1988.
Miles J F, Bright P, Ayres J G, Cayton R M, Miller M R. The performance of Mini Wright peak flow meters after prolonged use. Respir Med. 1995;89:603-5. [pmid: 7494912].
Miller M R, Dickinson S A, Hitchings D J. The accuracy of portable peak flow meters. Thorax. 1992;47:904-9. [pmid: 1465746].
Morris N V, Abramson M J, Strasser R P. Adequacy of control of asthma in a general practice. Is maximum peak expiratory flow rate a valid index of asthma severity?. Med J Aust. 1994;160:68-71. [pmid: 8309371].
National Heart, Lung, and Blood Institute. Nurses: Partners in Asthma Care. National Institutes of Health publication no. 95-3708. Bethesda, MD, 1995.
Plaut TF. Children With Asthma: A Manual for Parents. Amherst, MA: Pedipress, 1995, pp. 94–108.
Plaut TF. One Minute Asthma: What You Need To Know. Amherst, MA: Pedipress, 1991, pp. 12–13.
Quackenboss J J, Lebowitz M D, Krzyzanowski M. The normal range of diurnal changes in peak expiratory flow rates. Relationship to symptoms and respiratory disease. Am Rev Respir Dis. 1991;143:323-30. [pmid: 1990947].
Reddel H K, Salome C M, Peat J K, Woolcock A J. Which index of peak expiratory flow is most useful in the management of stable asthma?. Am J Respir Crit Care Med. 1995;151:1320-5. [pmid: 7735580].
Reeder K P, Dolce J J, Duke L, Raczynski J M, Bailey W C. Peak flow meters: are they monitoring tools or training devices?. J Asthma. 1990;27:219-27. [pmid: 2145262].
Richards J M Jr, Hemstreet M P. Measures of life quality, role performance, and functional status in asthma research. Am J Respir Crit Care Med. 1994;149:S31-9. [pmid: 8298767].
Rubinfeld A R, Pain M C. Perception of asthma. Lancet. 1976;1:882-4. [pmid: 58147].
Sly P D, Cahill P, Willet K, Burton P. Accuracy of mini peak flow meters in indicating changes in lung function in children with asthma. BMJ. 1994;308:572-4. [pmid: 8148680].
Stewart A L, Hays R D, Ware J E Jr. The MOS short-form general health survey. Reliability and validity in a patient population. Med Care. 1988;26:724-35. [pmid: 3393032].
Wall M A, Olson D, Bonn B A, Creelman T, Buist A S. Lung function in North American Indian children: reference standards for spirometry, maximal expiratory flow volume curves, and peak expiratory flow. Am Rev Respir Dis. 1982;125:158-62. [pmid: 7065517].
Woolcock A J, Colman M H, Blackburn C R. Factors affecting normal values for ventilatory lung function. Am Rev Respir Dis. 1972;106:692-709. [pmid: 5078869].
Woolcock A J, Yan K, Salome C M. Effect of therapy on bronchial hyperresponsiveness in the long-term management of asthma. Clin Allergy. 1988;18:165-76. [pmid: 3365860].