# Initial Assessment and Diagnosis of Asthma

Key Points
- To establish a diagnosis of asthma, the clinician should determine that:
  - Episodic symptoms of airflow obstruction are present.
  - Airflow obstruction is at least partially reversible.
  - Alternative diagnoses are excluded.
- Recommended mechanisms to establish the diagnosis are:
  - Detailed medical history
  - Physical exam focusing on the upper respiratory tract, chest, and skin
  - Spirometry to demonstrate reversibility
- Additional studies may be considered to:
  - Evaluate alternative diagnoses
  - Identify precipitating factors
  - Assess severity
  - Investigate potential complications
- Recommendations are presented for referral for consultation or care to a specialist in asthma care.

Differences from 1991 Expert Panel Report
- Severity classifications were changed from mild, moderate, and severe to mild intermittent, mild persistent, moderate persistent, and severe persistent.
- Examples of questions to use for diagnosis and initial assessment of asthma were added.
- Information on wheezing in infancy and vocal cord dysfunction was expanded in the differential diagnosis section.
- Criteria for referral were refined with input from specialty and primary care physicians.
- More specific recommendations for measuring peak expiratory flow (PEF) diurnal variation are made.

The guidelines to help establish a diagnosis of asthma presented in this component are based on the opinion of the Expert Panel.

The clinician trying to establish a diagnosis of asthma should determine that:

- Episodic symptoms of airflow obstruction are present.
- Airflow obstruction is at least partially reversible.
- Alternative diagnoses are excluded.

A careful medical history, physical examination, pulmonary function tests, and additional tests will provide the information needed to ensure a correct diagnosis of asthma (see box 3-1). Each of these methods of assessment is described in this section.

Clinical judgment is needed in conducting the assessment for asthma. Patients with asthma are heterogeneous and present signs and symptoms that vary widely from patient to patient as well as within each patient over time.

Box 3-1 Key Indicators for Considering a Diagnosis of Asthma

Consider asthma and performing spirometry if any of these indicators are present.^*^ These indicators are not diagnostic by themselves, but the presence of multiple key indicators increases the probability of a diagnosis of asthma. Spirometry is needed to establish a diagnosis of asthma.

* Eczema, hay fever, or a family history of asthma or atopic diseases are often associated with asthma, but they are not key indicators.

- Wheezing—high-pitched whistling sounds when breathing out—especially in children. (Lack of wheezing and a normal chest examination do not exclude asthma.)
- History of any of the following:
  - Cough, worse particularly at night
  - Recurrent wheeze
  - Recurrent difficulty in breathing
  - Recurrent chest tightness
- Reversible airflow limitation and diurnal variation as measured by using a peak flow meter, for example:
  - Peak expiratory flow (PEF) varies 20 percent or more from PEF measurement on arising in the morning (before taking an inhaled short-acting beta_2_-agonist) to PEF measurement in the early afternoon (after taking an inhaled short-acting beta_2_-agonist).
- Symptoms occur or worsen in the presence of:
  - Exercise
  - Viral infection
  - Animals with fur or feathers
  - House-dust mites (in mattresses, pillows, upholstered furniture, carpets)
  - Mold
  - Smoke (tobacco, wood)
  - Pollen
  - Changes in weather
  - Strong emotional expression (laughing or crying hard)
  - Airborne chemicals or dusts
  - Menses
- Symptoms occur or worsen at night, awakening the patient.

## Medical History

A detailed medical history of the new patient known or thought to have asthma should address the items listed in box 3-2. The medical history can help:

Box 3-2 Suggested Items for Medical History^*^ * This list does not represent a standardized assessment or diagnostic instrument. The validity and reliability of this list have not been assessed.

A detailed medical history of the new patient who is known or thought to have asthma should address the following items:

1. Symptoms
  Cough
  Wheezing
  Shortness of breath
  Chest tightness
  Sputum production
2. Pattern of symptoms
  Perennial, seasonal, or both
  Continual, episodic, or both
  Onset, duration, frequency (number of days or nights, per week or month)
  Diurnal variations, especially nocturnal and on awakening in early morning
3. Precipitating and/or aggravating factors
  Viral respiratory infections
  Environmental allergens, indoor (e.g., mold, house-dust mite, cockroach, animal dander or secretory products) and outdoor (e.g., pollen)
  Exercise
  Occupational chemicals or allergens
  Environmental change (e.g., moving to new home; going on vacation; and/or alterations in workplace, work processes, or materials used)
  Irritants (e.g., tobacco smoke, strong odors, air pollutants, occupational chemicals, dusts and particulates, vapors, gases, and aerosols)
  Emotional expressions (e.g., fear, anger, frustration, hard crying or laughing)
  Drugs (e.g., aspirin; beta-blockers, including eye drops; nonsteroidal anti-inflammatory drugs; others)
  Food, food additives, and preservatives (e.g., sulfites)
  Changes in weather, exposure to cold air
  Endocrine factors (e.g., menses, pregnancy, thyroid disease)
4. Development of disease and treatment
  Age of onset and diagnosis
  History of early-life injury to airways (e.g., bronchopulmonary dysplasia, pneumonia, parental smoking)
  Progress of disease (better or worse)
  Present management and response, including plans for managing exacerbations
  Need for oral corticosteroids and frequency of use
  Comorbid conditions
5. Family history
  History of asthma, allergy, sinusitis, rhinitis, or nasal polyps in close relatives
6. Social history
  Characteristics of home including age, location, cooling and heating system, wood-burning stove, humidifier, carpeting over concrete, presence of molds or mildew, characteristics of rooms where patient spends time (e.g., bedroom and living room with attention to bedding, floor covering, stuffed furniture)
  Smoking (patient and others in home or day care)
  Day care, workplace, and school characteristics that may interfere with adherence
  Social factors that interfere with adherence, such as substance abuse
  Social support/social networks
  Level of education completed
  Employment (if employed, characteristics of work environment)
7. Profile of typical exacerbation
  Usual prodromal signs and symptoms
  Usual patterns and management (what works?)
8. Impact of asthma on patient and family
  Episodes of unscheduled care (emergency department, urgent care, hospitalization)
  Life-threatening exacerbations (e.g., intubation, intensive care unit admission)
  Number of days missed from school/work
  Limitation of activity, especially sports and strenuous work
  History of nocturnal awakening
  Effect on growth, development, behavior, school or work performance, and lifestyle
  Impact on family routines, activities, or dynamics
  Economic impact
9. Assessment of patient's and family's perceptions of disease
  Patient, parental, and spouse's or partner's knowledge of asthma and belief in the chronicity of asthma and in the efficacy of treatment
  Patient perception and beliefs regarding use and long-term effects of medications
  Ability of patient and parents, spouse, or partner to cope with disease
  Level of family support and patient's and parents', spouse's, or partner's capacity to recognize severity of an exacerbation
  Economic resources
  Sociocultural beliefs

- Identify the symptoms likely to be due to asthma. See box 3-3 for sample questions.
- Support the likelihood of asthma (e.g., patterns of symptoms, family history of asthma or allergies).
- Assess the severity of asthma (e.g., symptom frequency and severity, exercise tolerance, hospitalizations, current medications). See table 3-1 for a description of the levels of asthma severity.
- Identify possible precipitating factors (e.g., viral respiratory infections; exposure at home, work, day care, or school to inhalant allergens or irritants such as tobacco smoke). See component 2, Control of Factors Contributing to Asthma Severity, for more details.

Box 3-3 Sample Questions^*^ * These questions are examples and do not represent a standardized assessment or diagnostic instrument. The validity and reliability of these questions have not been assessed. for the Diagnosis and Initial Assessment of Asthma

A “yes” answer to any question suggests that an asthma diagnosis is likely.

In the past 12 months, …

- Have you had a sudden severe episode or recurrent episodes of coughing, wheezing (high-pitched whistling sounds when breathing out), or shortness of breath?
- Have you had colds that “go to the chest” or take more than 10 days to get over?
- Have you had coughing, wheezing, or shortness of breath during a particular season or time of the year?
- Have you had coughing, wheezing, or shortness of breath in certain places or when exposed to certain things (e.g., animals, tobacco smoke, perfumes)?
- Have you used any medications that help you breathe better? How often?
- Are your symptoms relieved when the medications are used?
  In the past 4 weeks, have you had coughing, wheezing, or shortness of breath …
- At night that has awakened you?
- In the early morning?
- After running, moderate exercise, or other physical activity?

Table 3-1 Classification of Asthma Severity

Clinical Features Before Treatment*
| Symptoms** | Nighttime Symptoms | Lung Function
STEP 4 Severe Persistent | Continual symptoms | Frequent | FEV_1_ or PEF ≤60% predicted
| Limited physical activity | | PEF variability >30%
| Frequent exacerbations
STEP 3 Moderate Persistent | Daily symptoms | > 1 time a week | FEV_1_ or PEF >60% -<80% predicted
| Daily use of inhaled short-acting beta_2_-agonist | | PEF variability >30%
| Exacerbations affect activity
| Exacerbations ≥ 2 times a week; may last days
STEP 2 Mild Persistent | Symptoms >2 times a week but <1 time a day | >2 times a month | FEV_1_ or PEF ≥80% predicted
| Exacerbations may affect activity | | PEF variability 20–30%
STEP 1 Mild Intermittent | Symptoms ≤2 times a week | ≤2 times a month | FEV_1_ or PEF ≥80% predicted
| Asymptomatic and normal PEF between exacerbations | | PEF variability <20%
| Exacerbations brief (from a few hou to a few days); intensity may vary

* The presence of one of the features of severity is sufficient to place a patient in that category. An individual should be assigned to the most severe grade in which any feature occurs. The characteristics noted in this figure are general and may overlap because asthma is highly variable. Furthermore, an individual's classification may change over time.

** Patients at any level of severity can have mild, moderate, or severe exacerbations. Some patients with intermittent asthma experience severe and life-threatening exacerbations separated by long periods of normal lung function and no symptoms.

## Physical Examination

The upper respiratory tract, chest, and skin are the focus of the physical examination for asthma. Physical findings that increase the probability of asthma include:

- Hyperexpansion of the thorax, especially in children; use of accessory muscles; appearance of hunched shoulders; and chest deformity.
- Sounds of wheezing during normal breathing, or a prolonged phase of forced exhalation (typical of airflow obstruction). Wheezing during forced exhalation is not a reliable indicator of airflow limitation. In mild intermittent asthma, or between exacerbations, wheezing may be absent.
- Increased nasal secretion, mucosal swelling, and nasal polyps.
- Atopic dermatitis/eczema or any other manifestation of an allergic skin condition.

## Pulmonary Function Testing (Spirometry)

Spirometry measurements (FEV_1_, FVC, FEV_1_/FVC) before and after the patient inhales a short-acting bronchodilator should be undertaken for patients in whom the diagnosis of asthma is being considered (Bye et al. 1992;Li and O'Connell 1996). This helps determine whether there is airflow obstruction and whether it is reversible over the short term (see box 3-4 for further information). Spirometry is generally valuable in children over age 4; however, some children cannot conduct the maneuver adequately until after age 7.

Box 3-4 Importance of Spirometry in Asthma Diagnosis

Objective assessments of pulmonary function are necessary for the diagnosis of asthma because medical history and physical examination are not reliable means of excluding other diagnoses or of characterizing the status of lung impairment. Although physicians generally seem able to identify a lung abnormality as obstructive (Russell et al. 1986), they have a poor ability to assess the degree of airflow obstruction (Shim and Williams 1980) or to predict whether the obstruction is reversible (Russell et al. 1986).

For diagnostic purposes, spirometry is generally recommended over measurements by a peak flow meter in the clinician's office because there is wide variability even in the best published peak expiratory flow reference values. Reference values need to be specific to each brand of peak flow meter, and such normative brand-specific values currently are not available for most brands. Peak flow meters are designed as monitoring, not as diagnostic, tools in the office (see component 1-Periodic Assessment and Monitoring). However, peak flow monitoring can establish peak flow variability and thus aid in the determination of asthma severity when patients have asthma symptoms and normal spirometry (see Additional Studies section, page 19).

Spirometry typically measures the maximal volume of air forcibly exhaled from the point of maximal inhalation (forced vital capacity, FVC) and the volume of air exhaled during the first second of the FVC (forced expiratory volume in 1 second, FEV_1_). Airflow obstruction is indicated by reduced FEV_1_ and FEV_1_/FVC values relative to reference or predicted values. Significant reversibility is indicated by an increase of ≥ 12 percent and 200 mL in FEV_1_ after inhaling a short-acting bronchodilator (American Thoracic Society 1991) (see figures 3-1 and 3-2 for example of a spirometric curve for this test). A 2- to 3-week trial of oral corticosteroid therapy may be required to demonstrate reversibility. The spirometry measures that establish reversibility may not indicate the patient's best lung function.

Figure 3-1 Sample Spirometry Volume Time and Flow Volume Curves

Figure 3-2 Report of Spirometry Findings Pre and Post Bronchodilator

Abnormalities of lung function are categorized as restrictive and obstructive defects. A reduced ratio of FEV_1_/FVC (i.e., <65 percent) indicates obstruction to the flow of air from the lungs, whereas a reduced FVC with a normal FEV_1_/FVC ratio suggests a restrictive pattern. The severity of abnormality of spirometric measurements is evaluated by comparison of the patient's results with reference values based on age, height, sex, and race (American Thoracic Society 1991).

Although asthma is typically associated with an obstructive impairment that is reversible, neither this finding nor any other single test or measure is adequate to diagnose asthma. Many diseases are associated with this pattern of abnormality. The patient's pattern of symptoms (along with other information from the patient's medical history) and exclusion of other possible diagnoses also are needed to establish a diagnosis of asthma. In severe cases, the FVC may also be reduced, due to trapping of air in the lungs.

Office-based physicians who care for asthma patients should have access to spirometry, which is useful in both diagnosis and periodic monitoring. Spirometry should be performed using equipment and techniques that meet standards developed by the American Thoracic Society (1995). Correct technique, calibration methods, and maintenance of equipment are necessary to achieve consistently accurate test results. Maximal patient effort in performing the test is required to avoid important errors in diagnosis and management.

Training courses in the performance of spirometry that are approved by the National Institute for Occupational Safety and Health are available (800-35NIOSH). When office spirometry shows severe abnormalities, or if questions arise regarding test accuracy or interpretation, the Expert Panel recommends further assessment in a specialized pulmonary function laboratory.

## Additional Studies

Even though additional studies are not routine, they may be considered. No one test or set of tests is appropriate for every patient. However, the following procedures may be useful when considering alternative diagnoses, identifying precipitating factors, assessing severity, and investigating potential complications:

- Additional pulmonary function studies (e.g., lung volumes and inspiratory and expiratory flow volume loops) may be indicated, especially if there are questions about coexisting chronic obstructive pulmonary disease, a restrictive defect, or possible central airway obstruction. A diffusing capacity test is helpful in differentiating between asthma and emphysema in patients at risk for both illnesses, such as smokers and older patients.
- Assessment of diurnal variation in peak expiratory flow over 1 to 2 weeks is recommended when patients have asthma symptoms but normal spirometry (Enright et al. 1994). PEF is generally lowest on first awakening and highest several hours before the midpoint of the waking day (e.g., between noon and 2 p.m.) (Quackenboss et al. 1991). Optimally, PEF should be measured close to those two times, before taking an inhaled short-acting beta_2_-agonist in the morning and after taking one in the afternoon. A 20 percent difference between morning and afternoon measurements suggests asthma. Measuring PEF on waking and in the evening may be more practical and feasible, but values will tend to underestimate the actual diurnal variation.
- Bronchoprovocation with methacholine, histamine, or exercise challenge may be useful when asthma is suspected and spirometry is normal or near normal. For safety reasons, bronchoprovocation testing should be carried out by a trained individual in an appropriate facility and is not generally recommended if the FEV_1_ is <65 percent predicted. A negative bronchoprovocation may be helpful to rule out asthma.
- Chest x ray may be needed to exclude other diagnoses.
- Allergy testing (see component 2).
- Evaluation of the nose for nasal polyps and sinuses for sinus disease.
- Evaluation for gastroesophageal reflux (Harding and Richter 1992) (see component 2).

The usefulness of measurements of biomarkers of inflammation (e.g., total and differential cell count and mediator assays) in sputum, blood, or urine as aids to the diagnosis of asthma is currently being evaluated in clinical research trials.

## Differential Diagnosis of Asthma

Recurrent episodes of cough and wheezing are almost always due to asthma in both children and adults. Underdiagnosis of asthma is a frequent problem, especially in children who wheeze when they have respiratory infections. These children are often labeled as having bronchitis, bronchiolitis, or pneumonia even though the signs and symptoms are most compatible with a diagnosis of asthma. However, the clinician needs to be aware of other causes of airway obstruction leading to wheezing (see box 3-5).

Box 3-5 Differential Diagnostic Possibilities for Asthma

#### Infants and Children

##### Upper airway diseases

Allergic rhinitis and sinusitis

##### Obstructions involving large airways

Foreign body in trachea or bronchus

Vocal cord dysfunction

Vascular rings or laryngeal webs

Laryngotracheomalacia, tracheal stenosis, or bronchostenosis

Enlarged lymph nodes or tumor

##### Obstructions involving small airways

Viral bronchiolitis or obliterative bronchiolitis

Cystic fibrosis

Bronchopulmonary dysplasia

Heart disease

##### Other causes

Recurrent cough not due to asthma

Aspiration from swallowing mechanism dysfunction or gastroesophageal reflux

#### Adults

Chronic obstructive pulmonary disease (chronic bronchitis or emphysema)

Congestive heart failure

Pulmonary embolism

Laryngeal dysfunction

Mechanical obstruction of the airways (benign and malignant tumors)

Pulmonary infiltration with eosinophilia

Cough secondary to drugs (angiotensin-converting enzyme [ACE] inhibitors)

Vocal cord dysfunction

There are two general patterns of wheezing in infancy: nonallergic and allergic. Nonallergic infants wheeze when they have an acute upper respiratory viral infection, but as their airways grow larger in the preschool years the wheezing disappears. Allergic infants also wheeze with viral infections, but they are more likely to have asthma that will continue throughout childhood. This group may have eczema, allergic rhinitis, or food allergy as other manifestations of allergy. Both groups may benefit from asthma treatment (see Infants and Young Children section, page 94, in component 3-Managing Asthma Long Term).

Vocal cord dysfunction often mimics asthma. Patients with vocal cord dysfunction can present with recurrent severe shortness of breath and wheezing. Vocal cord dysfunction may even cause alveolar hypoventilation, with increases in PCO_2_ that prompt urgent intubation and mechanical ventilation. Vocal cord dysfunction that mimics asthma is more common in young adults with psychological disorders. It should be suspected when physical examination reveals a monophonic wheeze heard loudest over the glottis. Further evaluation by flow-volume curve revealing inspiratory flow limitation strongly supports the diagnosis of vocal cord dysfunction. Definitive diagnosis—and exclusion of organic causes of vocal cord narrowing—requires direct visualization of the vocal cords. Treatment with speech therapy that teaches techniques for relaxed throat breathing is often effective (Newman et al. 1995; Bucca et al. 1995; Christopher et al. 1983).

## General Guidelines for Referral to an Asthma Specialist

Criteria for the referral of an asthma patient have been developed (Spector and Nicklas 1995; Shuttari 1995). Based on the opinion of the Expert Panel, referral for consultation or care to a specialist in asthma care (usually, a fellowship-trained allergist or pulmonologist; occasionally, other physicians with expertise in asthma management developed through additional training and experience) is recommended when:

- Patient has had a life-threatening asthma exacerbation.
- Patient is not meeting the goals of asthma therapy (see component 1-Periodic Assessment and Monitoring) after 3 to 6 months of treatment. An earlier referral or consultation is appropriate if the physician concludes that the patient is unresponsive to therapy.
- Signs and symptoms are atypical or there are problems in differential diagnosis.
- Other conditions complicate asthma or its diagnosis (e.g., sinusitis, nasal polyps, aspergillosis, severe rhinitis, vocal cord dysfunction, gastroesophageal reflux, chronic obstructive pulmonary disease).
- Additional diagnostic testing is indicated (e.g., allergy skin testing, rhinoscopy, complete pulmonary function studies, provocative challenge, bronchoscopy).
- Patient requires additional education and guidance on complications of therapy, problems with adherence, or allergen avoidance.
- Patient is being considered for immunotherapy.
- Patient has severe persistent asthma, requiring step 4 care (referral may be considered for patients requiring step 3 care; see component 3-Managing Asthma Long Term).
- Patient requires continuous oral corticosteroid therapy or high-dose inhaled corticosteroids or has required more than two bursts of oral corticosteroids in 1 year.
- Patient is under age 3 and requires step 3 or 4 care (see component 3-Managing Asthma Long Term). When patient is under age 3 and requires step 2 care or initiation of daily long-term therapy, referral should be considered.
- Patient requires confirmation of a history that suggests that an occupational or environmental inhalant or ingested substance is provoking or contributing to asthma. Depending on the complexities of diagnosis, treatment, or the intervention required in the work environment, it may be appropriate in some cases for the specialist to manage the patient over a period of time or comanage with the primary care provider.

In addition, patients with significant psychiatric, psychosocial, or family problems that interfere with their asthma therapy may need referral to an appropriate mental health professional for counseling or treatment. These characteristics have been shown to interfere with a patient's ability to adhere to treatment (Strunk 1987; Strunk et al. 1985)

## References

American Thoracic Society. Lung function testing: selection of reference values and interpretive strategies. Am Rev Respir Dis. 1991;144:1202-18. [pmid: 1952453].
American Thoracic Society. Standardization of spirometry: 1994 update. Am J Respir Crit Care Med. 1995;152:1107-36. [pmid: 7663792].
Bucca C, Rolla G, Brussino L, De Rose V, Bugiani M. Are asthma-like symptoms due to bronchial or extrathoracic airway dysfunction?. Lancet. 1995;346:791-5. [pmid: 7674743].
Bye M R, Kerstein D, Barsh E. The importance of spirometry in the assessment of childhood asthma. Am J Dis Child. 1992;146:977-8. [pmid: 1636669].
Christopher K L, Wood R P 2nd, Eckert R C, Blager F B, Raney R A, Souhrada J F. Vocal cord dysfunction presenting as asthma. N Engl J Med. 1983;308:1566-70. [pmid: 6406891].
Enright P L, Lebowitz M D, Cockroft D W. Physiologic measures: pulmonary function tests. Asthma outcome. Am J Respir Crit Care Med. 1994;149:S9-18. [pmid: 8298772].
Harding S M, Richter J E. Gastroesophageal reflux disease and asthma. Semin Gastrointest Dis. 1992;3:139-50.
Knudson R J, Lebowitz M D, Holberg C J, Burrows B. Changes in the normal maximal expiratory flow-volume curve with growth and aging. Am Rev Respir Dis. 1983;127:725-34. [pmid: 6859656].
Li J T, O'Connell E J. Clinical evaluation of asthma. Ann Allergy Asthma Immunol. 1996;76:1-13. [pmid: 8564622].
Newman K B, Mason U G 3rd, Schmaling K B. Clinical features of vocal cord dysfunction. Am J Respir Crit Care Med. 1995;152:1382-6. [pmid: 7551399].
Quackenboss J J, Lebowitz M D, Krzyzanowski M. The normal range of diurnal changes in peak expiratory flow rates. Relationship to symptoms and respiratory disease. Am Rev Respir Dis. 1991;143:323-30. [pmid: 1990947].
Russell N J, Crichton N J, Emerson P A, Morgan A D. Quantitative assessment of the value of spirometry. Thorax. 1986;41:360-3. [pmid: 3750242].
Shim C S, Williams M H Jr. Evaluation of the severity of asthma: patients versus physicians. Am J Med. 1980;68:11-13. [pmid: 7350797].
Shuttari M F. Asthma: diagnosis and management. Am Fam Physician. 1995;52:2225-35. [pmid: 7484716].
Spector SL, Nicklas RA, eds. Practice parameters for the diagnosis and treatment of asthma. J Allergy Clin Immunol 1995;96:729–31.
Strunk R C. Asthma deaths in childhood: identification of patients at risk and intervention. J Allergy Clin Immunol. 1987;80:472-7. [pmid: 3624701].
Strunk R C, Mrazek D A, Wolfson Fuhrmann G S, LaBrecque J F. Physiologic and psychological characteristics associated with deaths due to asthma in childhood. A case-controlled study. JAMA. 1985;254:1193-8. [pmid: 4021061].