# Education for a Partnership in Asthma Care

Key Points
- Patient education should begin at the time of diagnosis and be integrated into every step of clinical asthma care.
- It is essential that education be provided by all members of the health care team. The principal clinician should introduce the key educational messages and negotiate agreements with patients; these messages should be reinforced and expanded by all members of the health care team.
- Teach asthma self-management, tailoring the approach to the needs of each patient. Maintain a sensitivity to cultural beliefs and practices.
- Teach and reinforce at every opportunity:
  - Basic facts about asthma
  - Roles of medications
  - Skills: inhaler/spacer/holding chamber use, self-monitoring
  - Environmental control measures
  - When and how to take rescue actions
- Jointly develop treatment goals.
- To encourage an active partnership, provide all patients with a written daily self-management plan and an action plan for exacerbations. Action plans are especially important for patients with moderate-to-severe asthma and patients with a history of severe exacerbations. Provide appropriate patients with a daily asthma diary.
- Encourage adherence by promoting open communication; individualizing, reviewing, and adjusting plans as needed; emphasizing goals and outcomes; and encouraging family involvement.

Differences from 1991 Expert Panel Report
- Emphasis is on patient education by the principal clinician as well as other members of the health care team.
- To enhance the delivery of education, detailed questions to elicit information and educational messages for each visit are provided in chart form. Reinforcement of key messages is emphasized.
- Additional emphasis is placed on evaluating outcomes in terms of patient perceptions of improvement, especially quality of life and the ability to engage in desired activities.
- Roles of written materials and formal education programs are clarified with emphasis that they can supplement but not replace education by clinicians. A list of sources for asthma education programs and materials is provided.
- Renewed emphasis is placed on providing patients with both a written treatment plan for daily self-management and a written action plan for management of exacerbations. Examples are provided that are applicable to both children and adults.
- New section on assessing and responding to cultural and language differences was added.
- New section on patient education for non-chlorofluorocarbon inhalers was added.

Patient education is an essential component of successful asthma management. Current management approaches require patients and families to effectively carry out complex pharmacologic regimens, institute environmental control strategies, detect and self-treat most asthma exacerbations, and communicate appropriately with health care providers. Patient education is the mechanism through which patients learn to successfully accomplish those tasks. It is also a powerful tool for helping patients gain the motivation, skill, and confidence to control their asthma (Feldman et al. 1987; Mellins 1989). Research shows that asthma education can be cost-effective and can reduce morbidity for both adults and children, especially among high-risk patients (Trautner et al. 1993; Bolton et al. 1991; Fireman et al. 1981; Hindi-Alexander and Cropp 1984; Lewis et al. 1984; Clark et al. 1986).

This component covers strategies for enhancing the delivery of patient education and improving the likelihood that patients will follow clinical recommendations, as well as key messages to communicate to the patient. When references are not cited, recommendations are based on the opinion of the Expert Panel.

## Establish a Partnership

Patient education should begin at the time of diagnosis and be integrated into every step of medical care, in the context of medical appointments and other clinician-patient communication. When clinicians take the time to provide education, it sends a powerful message to patients and families about the importance of being knowledgeable self-management of asthma. Specific educational messages delivered in the context of a medical care appointment clearly communicate the importance of collaboration in the treatment of asthma (Mayo et al. 1990; Ignacio-Garcia and Gonzales-Santos 1995). From the time of diagnosis, the clinician and other members of the health care team should begin to build a partnership with the patient and family. Building the partnership requires that clinicians promote open communication and ensure that patients have a basic and accurate foundation of knowledge about asthma, understand the treatment approach, and have the self-management skills necessary to monitor the disease objectively and take medication effectively (Evans et al. 1997).

When nurses, pharmacists, respiratory therapists, and other health care professionals are available to support and expand patient education (NHLBI 1995a, 1995b), a team approach should be used. The principal clinician should introduce the key educational messages (see box 9-1) and negotiate agreements with patients (Mayo et al. 1990; Kotses et al. 1996). Different members of the health care team should reinforce and expand these messages during office visits and telephone calls or in more formal educational sessions.

Box 9-1 Key Educational Messages for Patients

Check off or document that the following key messages have been covered:

#### Basic Facts About Asthma

The contrast between asthmatic and normal airways

What happens to the airways in an asthma attack

#### Roles of Medications

How medications work

- Long-term control: medications that prevent symptoms, often by reducing inflammation
- Quick relief: short-acting bronchodilator relaxes muscles around airways

Stress the importance of long-term-control medications and not to expect quick relief from them.

#### Skills

Inhaler use (patient demonstrate)

Spacer/holding chamber use

Symptom monitoring, peak flow monitoring, and recognizing early signs of deterioration

#### Environmental Control Measures

Identifying and avoiding environmental precipitants or exposures

#### When and How To Take Rescue Actions

Responding to changes in asthma severity (daily self-management plan and action plan)

Communication and coordination within the team are critical. Team members should document in the patient's record the key educational points (see box 9-1), patient concerns, and actions the patient agrees to take. This will enable all members of the team to be consistent and to reinforce the educational points and the progress being made.

### Teach Asthma Self-Management

The Expert Panel recommends that clinicians teach patients and families the essential information, medication skills, self-monitoring techniques, and environmental control measures outlined in table 9-1 (Bailey et al. 1990; Ignacio-Garcia and Gonzales-Santos 1995; Kotses et al. 1995, 1996; Wilson et al. 1993). These key points should be adapted to meet the individual patient's needs.

Table 9-1 Delivery of Asthma Education by Clinicians during Patient Care Visits

Assessment Questions | Information | Skills
Recommendations for Initial Visit
Focus on:; - Expectations of visit; - Goals of treatment; - Medications; - Quality of life | Teach in simple language: | Teach or review and demonstrate:
“What worries you most about your asthma?” | What is asthma? | Inhaler (see figure 9-1) and spacer/holding chamber use.
“What do you want to accomplish at this visit?” | A chronic lung disease. The airways are very sensitive. They become inflamed and narrow; breathing becomes difficult. | Check performance.
“What do you want to be able to do that you can't do now because of your asthma?” | Asthma treatments: two types of medicines are needed: | Self-monitoring skills that are tied to an action plan:
“What do you expect from treatment?” | - Long-term control: medications that prevent symptoms, often by reducing inflammation; - Quick relief: short-acting bronchodilator relaxes muscles around airways | - Recognize intensity and frequency of asthma symptoms; - Review the signs of deterioration and the need to reevaluate therapy:; - Waking at night with asthma; - Increased medication use; - Decreased activity tolerance
“What medicines have you tried?” | Bring all medications to every appointment. | Use of a simple, written self-management plan (see figures 9-2 and 9-3) and action plan (see figure 9-4)
“What other questions do you have for me today?” | When to seek medical advice. Provide appropriate telephone number.
Recommendations for First Followup Visit (2 to 4 weeks or sooner as needed)
Focus on:; - Expectations of visit; - Goals of treatment; - Medications; - Quality of life | Teach in simple language: | Teach or review and demonstrate:
Ask relevant questions from previous visit and also ask: | Use of two types of medications. Remind patient to bring all medications and the peak flow meter to every appointment for review. | Use of a daily self-management plan. Review and adjust as needed.
“What medications are you taking?” | Self-evaluation of progress in asthma control using symptoms and peak flow as a guide. | Use of an action plan. Review and adjust as needed.
“How and when are you taking them?” | | Peak flow monitoring (see box 4-2) and daily diary recording (see figure 4-2).
“What problems have you had using your medications?” | | Correct inhaler and spacer/holding chamber technique.
“Please show me how you use your inhaled medications.”
Recommendations for Second Followup Visit
Focus on:; - Expectations of visit; - Goals of treatment; - Medications; - Quality of life | Teach in simple language: | Teach or review and demonstrate:
Ask relevant questions from previous visits and also ask: | Relevant environmental control/avoidance strategies (see box 5-6). | Inhaler/spacer/holding chamber technique.
“Have you noticed anything in your home, work, or school that makes your asthma worse?” | - How to identify home, work, or school exposures that can cause or worsen asthma; - How to control house-dust mites, animal exposures if applicable; - How to avoid cigarette smoke (active and passive) | Peak flow monitoring technique.
“Describe for me how you know when to call your doctor or go to the hospital for asthma care.” | Review all medications. | Use of daily self-management plan. Review and adjust as needed.
“What questions do you have about the action plan?” “Can we make it easier?” | Review and interpret from daily diary: | Review use of action plan. Confirm that patient knows what to do if asthma gets worse.
“Are your medications causing you any problems?” | - Peak flow measure; - Symptom scores
Recommendations for All Subsequent Visits
Focus on:; - Expectations of visit; - Goals of treatment; - Medications; - Quality of life | Teach in simple language: | Teach or review and demonstrate:
Ask relevant questions from previous visits and also ask: | Review and reinforce all: | Inhaler/spacer/holding chamber technique.
“How have you tried to control things that make your asthma worse?” | - Educational messages; - Environmental control strategies at home, work, or school; - Medications | Peak flow monitoring technique.
“Please show me how you use your inhaled medication.” | Review and interpret from daily diary: | Use of daily self-management plan. Review and adjust as needed.
| - Peak flow measures; - Symptom scores | Review use of action plan. Confirm that patient knows what to do if asthma gets worse. Periodically review and adjust written action plan.

Figure 9-1 Steps for Using Your Inhaler

Please demonstrate your inhaler technique at every visit.

1. Remove the cap and hold inhaler upright.
2. Shake the inhaler.
3. Tilt your head back slightly and breathe out slowly.
4. Position the inhaler in one of the following ways (A or B is optimal, but C is acceptable for those who have difficulty with A or B. C is required for breath-activated inhalers):
5. Press down on the inhaler to release medication as you start to breathe in slowly.
6. Breathe in slowly (3 to 5 seconds).
7. Hold your breath for 10 seconds to allow the medicine to reach deeply into your lungs.
8. Repeat puff as directed. Waiting 1 minute between puffs may permit second puff to penetrate your lungs better.
9. Spacers/holding chambers are useful for all patients. They are particularly recommended for young children and older adults and for use with inhaled corticosteroids.

Avoid common inhaler mistakes. Follow these inhaler tips:

- Breathe out before pressing your inhaler.
- Inhale slowly.
- Breathe in through your mouth, not your nose.
- Press down on your inhaler at the start of inhalation (or within the first second of inhalation).
- Keep inhaling as you press down on inhaler.
- Press your inhaler only once while you are inhaling (one breath for each puff).
- Make sure you breathe in evenly and deeply.

Other inhalers are becoming available in addition to those illustrated above. Different types of inhalers may require different techniques.

Source: Expert Panel Report 2: Guidelines for the Diagnosis and Management of Asthma. National Asthma Education and Prevention Program, National Heart, Lung, and Blood Institute, 1997.

Figure 9-2

Figure 9-3

Figure 9-4

Clinicians should:

- Teach basic facts about asthma so that the patient and family understand the rationale for needed actions. Give a brief verbal description of what asthma is and the intended role of each medication. Do not overwhelm the patient with too much information all at once, but repeat the important messages at each visit. Ask the patient to bring all medications to each appointment for review.
- Teach the patient necessary medication skills, such as correct use of the inhaler (see figure 9-1) and spacer/holding chamber and knowing when and how to take quick- relief medications. (Also see box 9-2, Patient Education for Non-CFC Inhalers.)
- Teach self-monitoring skills: symptom monitoring, peak flow monitoring as appropriate (see component 1-Periodic Assessment and Monitoring), and recognizing early signs of deterioration.
- Teach relevant environmental control/avoidance strategies (see box 5-6). Teach how environmental precipitants or exposures can make the patient's asthma worse (e.g., allergens and irritants) at home, school, and work and how to recognize both immediate and delayed reactions.

Box 9-2 Patient Education for Non-CFC Inhalers

Clinicians need to be aware that metered-dose inhalers (MDIs) containing chlorofluorocarbons (CFCs) contribute to the depletion of stratospheric ozone. As a result of the consequent health hazards, CFCs have been internationally banned. Although a temporary medical exemption has been granted, MDIs with CFC propellants will eventually have to be replaced with alternative aerosol products, including MDIs with non-CFC propellants. Other non-CFC options include multidose dry powder inhalers and hand-held mini-nebulizers.

When first prescribing any of these new alternative products to patients accustomed to a CFC-containing MDI, the Expert Panel recommends that clinicians review with the patient the appropriate inhalation technique and care of the device to ensure proper use and optimum device performance. For alternative propellant MDIs, the patient may perceive differences in the aerosol delivery compared to their CFC-containing MDI. The patient should be given the following messages about these differences:

- All FDA-approved alternative propellant inhalers will have been demonstrated to be comparably safe and effective as their usual CFC-propelled medication in clinical trials. However, individual differences in tolerability may be observed.
- Clinicians should familiarize patients with any differences in the care and use of non-CFC devices.
- The alternative propelled MDIs may taste different or feel different due to differences in the propellant and formulations. However, patients should be assured that these differences should not lead to important differences in their use or benefit.

For alternate propellant MDIs that deliver a less forceful aerosol plume, patients may believe that this less forceful spray may not reach their lungs as effectively as their CFC product. Clinicians should reassure patients that medication delivery is assured by proper inhalation technique and that a less forceful spray does not equate with less efficacy. This is an opportunity to train patients in the use of non-CFC devices.

### Jointly Develop Treatment Goals

Fundamental to building a partnership is for clinicians and patients to jointly develop and agree on both short- and long-term treatment goals. Such agreements can encourage active participation, enhance the partnership, and improve asthma management (Schulman 1979; Clark 1989; Clark et al. 1995). It is the opinion of the Expert Panel that clinicians should:

- Determine the patient's personal treatment goals. Ask how asthma interferes with the patient's life (e.g., inability to sleep through the night, play a sport) and incorporate the responses into personal treatment goals. Asthma-specific quality-of-life instruments (Juniper et al. 1992; Marks et al. 1993) may be useful.
- Share the general goals of asthma treatment with the patient and family. Tell patients, “Our goals are to have you:
  - Be free from severe symptoms day and night, including sleeping through the night.”
  - Have the best possible lung function.”
  - Be able to participate fully in any activities of your choice.”
  - Not miss work or school because of asthma symptoms.”
  - Need fewer or no urgent care visits or hospitalizations for asthma.”
  - Use medications to control asthma with as few side effects as possible.”
  - Be satisfied with your asthma care.”
- Agree on the goals of treatment. The clinicians, the patient, and when appropriate, the patient's family should agree on the goals of asthma management, which include both the patient's personal goals and the general goals (see list above) suggested by the clinicians.

### Provide the Patient With Tools for Self-Management

It is the opinion of the Expert Panel that, at the first visit, clinicians should develop a written, individualized, daily self-management plan (see figures 9-2 and 9-3) in consultation with the patient. Include the recommended doses and frequencies of daily medications and the daily self-management activities needed to achieve the agreed-on goals. Review and refine the plan at subsequent followup visits. List the treatment goals in the plan and explain how following the plan will help the patient reach those goals. Emphasizing the patient's personal goals is essential to enhancing adherence. For example, ask, “Have you had any problems taking your bronchodilator immediately before playing basketball? Has it helped you stay in the game?”

Discuss the long-term benefits of following the written, daily self-management plan (Plaut 1996). For some patients, focusing on long-term treatment goals and discussing the “big picture” of asthma control and how medications can be adjusted over time may improve adherence (Mellins 1996).

Also at the first visit, jointly develop a written action plan to help the patient manage asthma exacerbations (see figure 9-4, pages 138–143) for examples). This is especially important for patients with moderate-to-severe persistent asthma and patients with a history of severe exacerbations. Review and refine the plan at followup visits. The action plan directs the patient to adjust medicines at home in response to particular signs, symptoms, and peak flow measurements. It should also list the PEF levels and symptoms indicating the need for acute care and emergency telephone numbers for the physician, emergency department, rapid transportation, and family/friend for aid and support. A number of action plans have been published (Woolcock et al. 1988; Beasley et al. 1989; D'Souza et al. 1994; Charlton et al. 1990; Mellins and Evans, in press; NHLBI 1995d; NHLBI 1995e). Those tested in randomized clinical trials were effective in decreasing asthma exacerbations (Woolcock et al. 1988; Charlton et al. 1990). Clinicians should choose an action plan that suits their practice, patients, and style. The examples in figure 9-4 are not endorsed by the Expert Panel; rather, they are provided to demonstrate a range of possibilities and should be modified as appropriate.

It is the opinion of the Expert Panel that clinicians should provide an asthma diary to appropriate patients for self-monitoring symptoms, peak flow measurements, frequency of daily quick-relief inhaler medication use, and activity restriction (see figure 4-2).

### Encourage Adherence

An important part of patient education is encouraging adherence.

- Use effective techniques to promote open communication. Research suggests that certain clinician behaviors are associated with patient adherence and/or satisfaction with care (Clark et al. 1995). Not all are appropriate for cultural subgroups, but the items listed in box 9-3 are general guidelines.
- Early in each visit, elicit the patient's concerns, perceptions, and unresolved questions about his or her asthma (see table 9-1). A question such as “What worries you most about your asthma?,” which cannot be answered yes or no, encourages patients and families to voice issues, personal beliefs, or concerns they may be apprehensive about discussing or may not think are of interest to the clinician. These potential barriers to adherence can be dealt with only if they are identified. By asking about and discussing such concerns, clinicians build trust and a sense of partnership with the patient. Most nonadherence originates in personal beliefs or concerns about asthma that have not been discussed with the clinician (Korsch et al. 1968; Janz et al. 1984). Until such fears and worries are identified and addressed, patients will not be able to adhere to the clinician's recommendations (Korsch et al. 1968).
- Assess the patient's and family's perceptions of the severity level of the disease. Two questions may prove useful: “How severe do you think your asthma is?” and “How much danger do you believe you are in from your asthma?” When patients are identified who are overwhelmed by fear of death, put their fears in perspective by providing them with the results of objective assessments and expert opinion. A clearly written, detailed action plan that directs the patient how to respond to worsening asthma may be extremely helpful in reducing anxiety (figure 9-4). Patients' perceptions about their disease severity and its threat to their well-being influence self-management behavior and use of the health care system (Janson-Bjerklie et al. 1992; Janz et al. 1984).
- Assess the patient's and family's level of social support. Ask, “Who among your family or friends can you turn to for help if your asthma worsens?” Counsel patients to identify an asthma “partner” among their family or friends who is willing to be educated and provide support. Include at least one of these individuals in followup appointments with the patient so that he or she can hear what is expected of the patient in following the self-management and action plans (Graham et al. 1990).
- Encourage or enlist family involvement. Ask patients to identify ways their family members can help them follow the plans. Ask the patient to share the plans with family members, elicit their input, and agree on actions they can help with. It may be helpful for children and parents to discuss this with a clinician present.
- Consider referral to a psychologist, social worker, psychiatrist, or other licensed professional when stress seems to unduly interfere with daily asthma management. As with other chronic diseases, emotional and social stress may be a confounding factor for many patients struggling with asthma control. Although stress does not cause asthma, it can play a role in precipitating asthma exacerbations (Busse et al. 1995) and can complicate an individual's attempts at self-management. Referral to a local support group may be useful.
- Use methods to increase the chances that the patient will adhere to the written, daily self-management plan. For instance, adherence to the self-management plan is enhanced when the plan is simplified as much as possible, when the number of medications and frequency of daily doses are minimized, when the medication doses and frequency fit into the patient's and family's daily routine (Clark et al. 1995; Haynes et al. 1979; Eisen et al. 1990; Evans 1993; Meichenbaum and Turk 1987), and when the plan considers the patient's ability to afford the medications (Hindi-Alexander and Throm 1987). Because nonadherence is difficult for clinicians to detect (Haynes et al. 1979; Charney et al. 1967; Mushlin and Appel 1977), it is prudent to explore potential barriers to adherence with every patient by asking what concerns they have about medicines (e.g., safety) or other aspects of treatment.

Box 9-3 Promoting Open Communication to Encourage Patient Adherence

##### Friendly Manner

Show attentiveness (eye contact, attentive listening, etc.)

Give encouragements with nonverbal communication (nodding agreement, smiling, etc.)

Give verbal praise for effective management strategies

Use interactive conversation (e.g., asking open-ended questions)

##### Reassuring Communication

Elicit patient's underlying concerns about asthma

Allay fears with specific reassuring information

Adapted with permission from Clark et al. 1995.

### Tailor Education to the Needs of the Individual Patient

Assess cultural or ethnic beliefs or practices that may influence self-management activities and modify educational approaches, as needed. Cultural variables may affect patient understanding of and adherence to medical regimens (Pachter and Weller 1993; Kleinman et al. 1978). Open-ended questions such as “In your community, what does having asthma mean?” can elicit informative responses. The culturally sensitive clinician should attempt to find ways to incorporate harmless or potentially beneficial remedies with the pharmacologic plan. For example, a prevalent belief among the Latino population is that illnesses are either “hot” or “cold” (Risser and Mazur 1995). Asthma is viewed as a “cold” illness amenable to “hot” treatment. Suggesting that asthma medications be taken with hot tea or hot water incorporates this belief into the therapeutic regimen and helps build the therapeutic partnership. When harmful home remedies are being used, clinicians should discourage their use by suggesting a culturally acceptable alternative as a replacement or recommending a safer route of administration (Pachter et al. 1995). These and other strategies may be useful in working with ethnic minorities (NHLBI 1995c).

Every effort should be made to discuss asthma care, especially the self-management plan, in the patient's native language so that educational messages are fully understood. Research suggests that lack of language concordance between the clinician and the patient affects adherence and appropriate use of health care services (Manson 1988). Language barriers also may complicate the assessment of cultural differences. If interpreters are used, they should be equally competent in both English and the patient's language and knowledgeable about medical terms (Woloshin et al. 1995).

## Maintain the Partnership

As part of ongoing care, the clinician should continue to build the partnership by being a sympathetic coach and by helping the patient follow the self-management plan and take other needed actions. Educational efforts should be continuous, because it may take up to 6 months for the impact of education to be evident (Toelle et al. 1993). Furthermore, it is necessary to periodically review information and skills covered previously because patient self-management behavior is likely to decline over time (Reis et al. 1995).

In particular, it is essential that clinicians demonstrate, review, evaluate, and correct inhaler/spacer/ holding chamber technique at each visit because these skills deteriorate rapidly (Keston et al. 1993). Written instructions are helpful (see figure 9-1), but insufficient (Nimmo et al. 1993; Wilson et al. 1993). Research suggests that patients tend to make specific mistakes in using inhalers that need to be corrected (Larsen et al. 1994; Dolovich et al. 1981; Kesten et al. 1993; Hanania et al. 1994). Patients especially need to be reminded to inhale slowly and to activate the inhaler only once for each breath (Rau et al. 1996).

Clinicians should continue to promote open communication with the patient and family by addressing the following elements (see table 9-1) in each followup visit:

- Continue asking patients early in each visit what concerns they have about their asthma and what they especially want addressed during the visit.
- Review the short-term goals agreed on in the initial visit. Assess how well they are being achieved (e.g., was the patient's wish to engage in physical activity achieved?). Revise the goals as needed. Achievement of short-term goals should be discussed as indicators that the patient is moving toward long-term goals. Give positive verbal reinforcement for achievement of a goal and recognize the patient's success in moving closer to full control of the disease.
- Review the daily self-management plan and the steps the patient was to take (Clark et al. 1995). Adjust the plan as needed (e.g., the recommendations of how to use medicines if the dose or type is not working). Identify other problems the patient has in following the agreed-on steps (e.g., disguising the bad taste of medicine); treat these as areas needing more work, not as adherence failures. Write a self-management plan to help school personnel manage a child's asthma (see figure 9-5, page 144, for an example).
- Periodically review the asthma action plan and revise as necessary. Confirm that the patient knows what to do if his or her asthma gets worse.
- Continue teaching and reinforcing key educational messages (see box 9-1). Provide information and teach skills over several visits so as not to overwhelm the patient with too much information at one time. Repeat important points often.
- Give patients simple, brief written materials that reinforce the actions recommended and skills taught (Morris et al. 1986; Ley 1972; Davis et al. 1990; Estey et al. 1991). Table 9-2 (page 146) lists organizations that distribute patient education materials; many of these organizations also have some Spanish-language materials.

Figure 9-5

Table 9-2 Sources of Patient Education Programs and Materials

Organization | Validated Program(s); Age Group | Other written and audiovisual patient education materials? (in other languages?) | Local support groups?
American Lung Association | Open Airways at School; 8–11 years (Evans et al. 1987) | Yes (Yes) | Yes
For the affiliate nearest you, call (800) LUNG-USA [800-586-4872}
Asthma and Allergy Foundation of America | Asthma Care Training for Kids (A.C.T.); 7–12 years (Lewis et al.1984) | Yes (Yes) | Yes
1125 15th Street, N.W, Suite 502
Washington, DC 20005
(800) 7-ASTHMA {800-727-8462} | You Can Control Asthma; 8–12 years (Taggart et al. 1991)
National Technical Information Service | Air Power; 9–13 years (Wilson-Pessano and McNabb 1985; NHLBI 1984c) | Yes (Yes) | No
5285 Port Royal Road
Springfield, VA 22161
(703) 487-4650
| Air Wise; 8–13 years (McNabb et al. 1985; NHLBI 1984a)
| Living With Asthma; 8–13 years (Creer et al. 1988; NHLBI 1985)
| Open Airways; 4–12 years (Clark et al. 1986; NHLBI 1984a)
National Asthma Education and Prevention Program | Breathe Easier; adult (Wilson et al. 1993) | Yes (Yes) | No
National Heart, Lung, and Blood Institute Information Center
P.O. Box 30105
Bethesda, MD 20824-0105
(301) 251-1222
Allergy and Asthma Network/Mothers of Asthmatics, Inc. | No validated programs | Yes (Yes) | No
3554 Chain Bridge Road, Suite 200
Fairfax, VA 22030-2709
(800) 878-4403
American Academy of Allergy, Asthma, and Immunology | No validated programs | Yes (No) | No
611 East Wells Street
Milwaukee, WI 53202
(800) 822-ASTHMA {800-822-2762}
American College of Allergy, Asthma, and Immunology | No validated programs | Yes (No) | No
85 West Algonquin Road
Arlington Heights, IL 60005
(800) 842-7777
National Jewish Medical and Research Center | No validated programs | Yes (No) | No
1400 Jackson Street
Denver, CO 80206
(800) 423-8891

## Supplement Patient Education Delivered by Clinicians

All patients may benefit from a formal asthma education program that has been evaluated and reported in the literature to be effective. These programs should be taught by qualified asthma educators who are knowledgeable about asthma and experienced in patient education. Communication among the asthma educator, the clinicians providing direct care, and the patient/family is critical. When formal programs are available in local communities, they can supplement, but not replace, patient education provided in the office. Individual and group programs have been developed and tested for patients of all ages, including parents of very young children (birth to 4 years) (Clark et al. 1986; Creer et al. 1988; Evans et al. 1987; Lewis et al. 1984; NHLBI 1984a, 1984b, 1984c, 1985; Taggart et al. 1991; Wilson-Pessano et al. 1987; Wilson-Pessano and McNabb 1985; Bailey et al. 1990; Kotses et al. 1995; Wilson et al. 1996; Lahdensuo et al. 1996). A list of organizations distributing programs that have been validated in the literature can be found in table 9-2.

These patient education programs should be delivered as designed. Some validity and effectiveness may be compromised when segments of various programs are pieced together or when programs are condensed. In the interest of saving time, educators should not delete educational strategies, such as using small groups or scheduling multiple sessions spaced with “homework” assignments, because these strategies have demonstrated effectiveness in motivating individuals to make significant behavior changes (Thapar 1994; Wilson et al. 1993; Kotses et al. 1995; Bailey et al. 1990).

A variety of other educational formats, such as videotapes (Yoon et al. 1993) and interactive computer software (Osman et al. 1994), also may enhance, but not replace, education delivered by clinicians.

## Provide Patient Education in Other Clinical Settings

Patient education also should be delivered in the context of emergency department visits and hospitalizations. Asthma exacerbations may represent teachable moments when patients are more receptive to educational messages. Research on adults with asthma who are referred by emergency department providers to an asthma education program shows that education can decrease utilization of emergency services (Bolton et al. 1991). Educational programs delivered to hospitalized children and adult asthma patients show increased knowledge and use of self-management behaviors (Taggart et al. 1991), reduced length of hospital stay, and overall reduction in asthma readmissions (Mayo et al. 1996).

## References

Bailey W C, Richards J M Jr, Brooks C M, Soong S J, Windsor R A, Manzella B A. A randomized trial to improve self-management practices of adults with asthma. Arch Intern Med. 1990;150:1664-8. [pmid: 2200380].
Beasley R, Cushley M, Holgate S T. A self management plan in the treatment of adult asthma. Thorax. 1989;44:200-4. [pmid: 2705150].
Bolton M B, Tilley B C, Kuder J, Reeves T, Schultz L R. The cost and effectiveness of an education program for adults who have asthma. J Gen Intern Med. 1991;6:401-7. [pmid: 1744753].
Busse W W, Kiecolt-Glaser J K, Coe C L, Martin R J, Weiss R T, Parker S R. NHLBI workshop summary. Stress and asthma. Am J Respir Crit Care Med. 1995;151:249-52. [pmid: 7812562].
Charlton I, Charlton G, Broomfield J, Mullee M A. Evaluation of peak flow and symptoms only self management plans for control of asthma in general practice. BMJ. 1990;301:1355-9. [pmid: 2148702].
Charney E, Bynum R, Eldredge D, et al. How well do patients take oral penicillin? A collaborative study in private practice. Pediatrics. 1967;40(2):188-95. [pmid: 5006583].
Clark N M. Asthma self-management education. Research and implications for clinical practice. Chest. 1989;95(5):1110-3. [pmid: 2651035].
Clark N M, Feldman C H, Evans D, Levison M J, Wasilewski Y, Mellins R B. The impact of health education on frequency and cost of health care use by low income children with asthma. J Allergy Clin Immunol. 1986;78(1):108-15. [pmid: 3088085].
Clark N M, Nothwehr F, Gong M, et al. Physician-patient partnership in managing chronic illness. Acad Med. 1995;70(11):957-9. [pmid: 7575946].
Creer T L, Backial M A, Burns K L, et al. Living with asthma. I. Genesis and development of a self-management program for childhood asthma. J Asthma. 1988;25:335-62. [pmid: 3235422].
Davis T C, Crouch M A, Wills G, Miller S, Abdehou M. The gap between patient reading comprehension and the readability of patient education materials. J Fam Pract. 1990;31:533-8. [pmid: 2230677].
Dolovich M, Ruffin R E, Roberts R, Newhouse M T. Optimal delivery of aerosols from metered dose inhalers. Chest. 1981;80(6):911-5. [pmid: 7307637].
D'Souza W, Crane J, Burgess C, et al. Community-based asthma care: trial of a “credit card” asthma self-management plan. Eur Respir J. 1994;7:1260-5. [pmid: 7925904].
Eisen S A, Miller D K, Woodward R S, Spitznagel E, Przybeck T R. The effect of prescribed daily dose frequency on patient medication compliance. Arch Intern Med. 1990;150(9):1881-4. [pmid: 2102668].
Estey A, Musseau A, Keehn L. Comprehension levels of patients reading health information. Patient Educ Couns. 1991;18:165-9.
Evans D. To help patients control asthma the clinician must be a good listener and teacher [editorial]. Thorax. 1993;48:685-7. [pmid: 8153913].
Evans D, Clark N M, Feldman C H, et al. A school health education program for children with asthma aged 8–11 years. Health Educ Q. 1987;14(3):267-79. [pmid: 3654234].
Evans D, Mellins R, Lobach K, et al. Improving care for minority children with asthma: professional education in public health clinics. Pediatrics. 1997;99(2):157-64. [pmid: 9024439].
Feldman C H, Clark N M, Evans D. The role of health education in medical management of asthma. Some program applications. Clin Rev Allergy. 1987;5:195-205. [pmid: 3304602].
Fireman P, Friday G A, Gira C, Vierthaler W A, Michaels L. Teaching self-management skills to asthmatic children and their parents in an ambulatory care setting. Pediatrics. 1981;68:341-8. [pmid: 6792585].
Graham N M, Woodward A J, Ryan P, Douglas R M. Acute respiratory illness in Adelaide children. II: The relationship of maternal stress, social supports and family functioning. Int J Epidemiol. 1990;19(4):937-44. [pmid: 2084025].
Hanania N A, Wittman R, Kesten S, Chapman K R. Medical personnel's knowledge of and ability to use inhaling devices. Metered-dose inhalers, spacing chambers, and breath-actuated dry powder inhalers. Chest. 1994;105(1):111-6. [pmid: 8275720].
Haynes RB, Taylor DW, Sackett DL, eds. Compliance in Health Care. Baltimore, MD: Johns Hopkins University Press, 1979.
Hindi-Alexander M C, Cropp G J A. Evaluation of a family asthma program. J Allergy Clin Immunol. 1984;74:505-10. [pmid: 6491096].
Hindi-Alexander M C, Throm J. Compliance or noncompliance: that is the question!. Am J Health Promotion. 1987;1(4):5-11. [pmid: 22208365].
Ignacio-Garcia J M, Gonzales-Santos P. Asthma self-management education program by home monitoring of peak expiratory flow. Am J Respir Crit Care Med. 1995;151:353-9. [pmid: 7842191].
Janson-Bjerklie S, Ferketich S, Benner P, Becker G. Clinical markers of asthma severity and risk: importance of subjective as well as objective factors. Heart Lung. 1992;21:265-72. [pmid: 1592618].
Janz N K, Becker M H, Hartman P E. Contingency contracting to enhance patient compliance: a review. Patient Educ Counsel. 1984;5(4):165-78.
Juniper E F, Guyatt G H, Epstein R S, Ferrie P J, Jaeschke R, Hiller T K. Evaluation of impairment of health related quality of life in asthma: development of a questionnaire for use in clinical trials. Thorax. 1992;47:76-83. [pmid: 1549827].
Kesten S, Zive K, Chapman K R. Pharmacist knowledge and ability to use inhaled medication delivery systems. Chest. 1993;104(6):1737-42. [pmid: 8252954].
Kleinman A, Eisenberg L, Good B. Culture, illness, and care: clinical lessons from anthropologic and cross-cultural research. Ann Intern Med. 1978;88:251-8. [pmid: 626456].
Korsch B M, Gozzi E K, Francis V. Gaps in doctor-patient communication. I. Doctor-patient interaction and patient satisfaction. Pediatrics. 1968;42(5):855-71. [pmid: 5685370].
Kotses H, Bernstein I L, Bernstein D I, et al. A self-management program for adult asthma. Part I: Development and evaluation. J Allergy Clin Immunol. 1995;95(2):529-40. [pmid: 7852669].
Kotses H, Stout C, McConnaughy K, Winder J A, Creer T L. Evaluation of individualized asthma self-management programs. J Asthma. 1996;33:113-8. [pmid: 8609098].
Lahdensuo A, Haahtela T, Herrala J, et al. Randomised comparison of guided self management and traditional treatment of asthma over one year. BMJ. 1996;312:748-52. [pmid: 8605463].
Larsen J S, Hahn M, Ekholm B, Wick K A. Evaluation of conventional press-and-breathe metered-dose inhaler technique in 501 patients. J Asthma. 1994;31(3):193-9. [pmid: 8195061].
Lewis C E, Rachelefsky G, Lewis M A, de la Sota A, Kaplan M. A randomized trial of A.C.T. (Asthma Care Training) for kids. Pediatrics. 1984;74:478-86. [pmid: 6384911].
Ley H. Primacy, rated importance, and the recall of medical statements. J Health Soc Behav. 1972;13:311-7.
Manson A. Language concordance as a determinant of patient compliance and emergency room use in patients with asthma. Med Care. 1988;26(12):1119-28. [pmid: 3199910].
Marks G B, Dunn S M, Woolcock A J. An evaluation of an asthma quality of life questionnaire as a measure of change in adults with asthma. J Clin Epidemiol. 1993;46(10):1103-11. [pmid: 8410095].
Mayo P H, Richman J, Harris H W. Results of a program to reduce admissions for adult asthma. Ann Intern Med. 1990;112:864-71. [pmid: 2344111].
Mayo P H, Weinberg B J, Kramer B, Richman J, Seibert-Choi O -S, Rosen M J. Results of a program to improve the process of inpatient care of adult asthmatics. Chest. 1996;110:48-52. [pmid: 8681662].
McNabb W L, Wilson-Pessano S R, Hughes G W, Scamagas P. Self-management education of children with asthma: AIR WISE. Am J Public Health. 1985;75:1219-20. [pmid: 4037168].
Meichenbaum D, Turk D. Facilitating Treatment Adherence: A Practitioners Guidebook. New York: Plenum Press, 1987.
Mellins RB. Patient education is key to successful management of asthma. J Rev Respir Dis 1989;(Suppl):S47–S52.
Mellins R B. Developing a therapeutic plan for asthma in a primary-care setting. City Health Info. 1996;15:4-6.
Mellins RB, Evans D. The role of health education in the management of asthma. In: Taussig LM, Landau L, eds. Pediatric Respiratory Medicine. St. Louis, MO: Mosby, in press.
Morris LA, Grossman R, Barkdoll GL, Gordon E. A National Survey of Prescription Drug Information Provided to Patients. Food and Drug Administration, Rockville, MD 1986. OPE study 73, May 1986.
Mushlin A L, Appel F A. Diagnosing potential noncompliance. Physicians' ability in a behavioral dimension of medical care. Arch Intern Med. 1977;137(3):318-21. [pmid: 843149].
National Heart, Lung, and Blood Institute. Asthma Management and Prevention: A Practical Guide for Public Health Officials and Health Care Professionals. National Institutes of Health pub. no. 96-3659A. Bethesda, MD, 1995d.
National Heart, Lung, and Blood Institute. Asthma Management in Minority Children: Practical Insights for Clinicians, Researchers, and Public Health Planners. National Institutes of Health pub. no. 95-3675. Bethesda, MD, 1995c.
National Heart, Lung, and Blood Institute. Air Power: Self-Management of Asthma Through Group Education. National Institutes of Health pub no 85-2362. Bethesda, MD, 1984c.
National Heart, Lung, and Blood Institute. Air Wise: Management of Asthma Through Individual Education. National Institutes of Health pub no 84-2363. Bethesda, MD, 1984a.
National Heart, Lung, and Blood Institute. Global Initiative for Asthma. Global Strategy for Asthma Management and Prevention. NHLBI/WHO Workshop Report. National Institutes of Health pub no 95-3659. Bethesda, MD, 1995e.
National Heart, Lung, and Blood Institute. Living With Asthma: Manual for Teaching Families the Self-Management of Childhood Asthma. National Institutes of Health pub no 85-2364. Bethesda, MD, 1985.
National Heart, Lung, and Blood Institute. Nurses: Partners in Asthma Care. National Institutes of Health pub no 95-3308. Bethesda, MD, 1995a.
National Heart, Lung, and Blood Institute. Open Airways/Respiro Abierto: Asthma Self-Management Program. National Institutes of Health pub no 84-2365. Bethesda, MD, 1984b.
National Heart, Lung, and Blood Institute. The Role of the Pharmacist in Improving Asthma Care. National Institutes of Health pub no 95-3280. Bethesda, MD, 1995b.
Nimmo C J R, Chen D N M, Martinusen S M, Ustad T L, Ostrow D N. Assessment of patient acceptance and inhalation technique of a pressurized aerosol inhaler and two breach-actuated devices. Ann Pharmacother. 1993;27:922-7. [pmid: 8364279].
Osman L M, Abdalla M I, Beattie J A G, et al. Reducing hospital admission through computer supported education for asthma patients. BMJ. 1994;308(6928):568-71. [pmid: 8093148].
Pachter L M, Cloutier M M, Bernstein B A. Ethnomedical (folk) remedies for childhood asthma in a mainland Puerto Rican community. Arch Pediatr Adolesc Med. 1995;149:982-8. [pmid: 7655603].
Pachter L M, Weller S C. Acculturation and compliance with medical therapy. Dev Behav Pediatr. 1993;14(3):163-8.
Plaut T F. Asthma peak flow diary improves care. Ann Allergy Asthma Immunol. 1996;76:476-8. [pmid: 8630725].
Plaut TF, Brennan C. Asthma Charts and Forms. Amherst, MA: Pedipress, Inc., 1996.
Rau J L, Restrepo R D, Deshpand E V. Inhalation of single vs. multiple metered dose bronchodilator actuations from reservoir devices. An in vitro study. Chest. 1996;109:969-74. [pmid: 8635379].
Ries A L, Kaplan R M, Limberg T E, Prewitt L M. Effects of pulmonary rehabilitation on physiologic and psychosocial outcomes in patients with chronic obstructive pulmonary disease. Ann Intern Med. 1995;122(11):823-832. [pmid: 7741366].
Risser A L, Mazur L J. Use of folk remedies in a Hispanic population. Arch Pediatr Adolesc Med. 1995;149:978-81. [pmid: 7655602].
Schulman B A. Active patient orientation and outcomes in hypertensive treatment. Application of a socio-organizational perspective. Med Care. 1979;17(3):267-80. [pmid: 763004].
Taggart V S, Zuckerman A E, Sly R M, et al. You can control asthma: evaluation of an asthma education program for hospitalized inner-city children. Patient Educ Counsel. 1991;17:35-47.
Thapar A. Educating asthmatic patients in primary care: a pilot study of small group education. Fam Pract. 1994;11(1):39-43. [pmid: 8034151].
Toelle B G, Peat J K, Salome C M, Mellis C M, Bauman A E, Woodcock A J. Evaluation of a community-based asthma management program in a population sample of school-children. Med J Austr. 1993;158:742-6.
Trautner C, Richter B, Berger M. Cost-effectiveness of a structured treatment and teaching programme on asthma. Eur Respir J. 1993;6:1485-91. [pmid: 8112443].
Wilson S R, Latini D, Starr N J, et al. Education of parents of infants and very young children with asthma: a developmental evaluation of the Wee Wheezers program. J Asthma. 1996;33(4):239-54. [pmid: 8707779].
Wilson S R, Scamagas P, German D F, et al. A controlled trial of two forms of self-management education for adults with asthma. Am J Med. 1993;94:564-76. [pmid: 8506881].
Wilson-Pessano S R, McNabb W L. The role of patient education in the management of childhood asthma. Prev Med. 1985;14:670-87. [pmid: 3911197].
Wilson-Pessano S R, Scamagas P, Arsham G M, et al. An evaluation of approaches to asthma self-management education for adults: the AIR/Kaiser-Permanente study. Health Educ Q. 1987;14(3):333-43. [pmid: 3115916].
Woloshin S, Bickell N A, Schwartz L M, Gany F, Welch H G. Language barriers in medicine in the United States. JAMA. 1995;273(9):724-8. [pmid: 7853631].
Woolcock A J, Yan K, Salome C M. Effect of therapy on bronchial hyperresponsiveness in the long-term management of asthma. Clin Allergy. 1988;18:165-76. [pmid: 3365860].
Yoon R, McKenzie D K, Bauman A, Miles D A. Controlled trial evaluation of an asthma education programme for adults. Thorax. 1993;48:1110-6. [pmid: 8296253].