# Pathogenesis and Definition

Key Points
- Asthma, whatever the severity, is a chronic inflammatory disorder of the airways. This has implications for the diagnosis, management, and potential prevention of the disease.
- The immunohistopathologic features of asthma include:
  - Denudation of airway epithelium
  - Collagen deposition beneath basement membrane
  - Edema
  - Mast cell activation
  - Inflammatory cell infiltration
    - Neutrophils (especially in sudden-onset, fatal asthma exacerbations)
    - Eosinophils
    - Lymphocytes (TH2-like cells)
- Airway inflammation contributes to airway hyperresponsiveness, airflow limitation, respiratory symptoms, and disease chronicity.
- Airway inflammation also contributes to several forms of airflow limitation, including acute bronchoconstriction, airway edema, mucus plug formation, and airway wall remodeling. These features lead to bronchial obstruction.
- Atopy, the genetic predisposition for the development of an IgE-mediated response to common aeroallergens, is the strongest identifiable predisposing factor for developing asthma.

Differences from 1991 Expert Panel Report
- The critical role of inflammation in asthma has been further substantiated by research. It is recognized that asthma results from complex interactions among inflammatory cells, mediators, and other cells and tissues resident in the airway.
- Evidence indicates that subbasement membrane fibrosis may occur in some patients and that these changes contribute to persistent abnormalities in lung function. The importance of airway remodeling and the development of persistent airflow limitation need further exploration and may have significant implications for the treatment of asthma.

The clinician, physiologist, immunologist, and pathologist all may have different perspectives on asthma based on their individual viewpoints and experience. The merging of these different perspectives into an acceptable definition of asthma has begun to occur and is important for more specific and effective treatment of this disease and for investigation into its pathogenesis. Furthermore, even though this disorder affects virtually the entire spectrum of life, asthma has certain age-specific characteristics and differential diagnosis issues that need to be considered in both its treatment and its etiology.

Based on current knowledge, a working definition of asthma is: Asthma is a chronic inflammatory disorder of the airways in which many cells and cellular elements play a role, in particular, mast cells, eosinophils, T lymphocytes, macrophages, neutrophils, and epithelial cells. In susceptible individuals, this inflammation causes recurrent episodes of wheezing, breathlessness, chest tightness, and coughing, particularly at night or in the early morning. These episodes are usually associated with widespread but variable airflow obstruction that is often reversible either spontaneously or with treatment. The inflammation also causes an associated increase in the existing bronchial hyperresponsiveness to a variety of stimuli (NHLBI 1995). Moreover, recent evidence indicates that subbasement membrane fibrosis may occur in some patients with asthma and that these changes contribute to persistent abnormalities in lung function (Roche 1991).

This working definition and its expanded recognition of key features of asthma have been derived from studying how airway changes in asthma relate to various factors associated with the development of allergic inflammation (e.g., allergens, respiratory viruses, and some occupational exposures, as illustrated in figure 1). From this approach has come a more comprehensive understanding of asthma pathogenesis, the development of persistent airway inflammation, and the profound implications these issues have for the diagnosis, treatment, and potential prevention of asthma.

Figure 1 Mechanisms Underlying the Definition of Asthma

Adapted with permission from Stephen T. Holgate, M.D., D.Sc.

## Airway Pathology and Asthma

Until recently, information on airway pathology in asthma has come largely from post-mortem examination (Dunnill 1960), which shows that both large and small airways often contain plugs composed of mucus, serum proteins, inflammatory cells, and cellular debris. Viewed microscopically, airways are infiltrated with eosinophils and mononuclear cells, and there is vasodilation and evidence of microvascular leakage and epithelial disruption. The airway smooth muscle is often hypertrophied, which is characterized by new vessel formation, increased numbers of epithelial goblet cells, and deposition of interstitial collagens beneath the epithelium. These features of airway wall remodeling further underscore the importance of chronic, recurrent inflammation in asthma and its effects on the airway. Moreover, these morphologic changes may not be completely reversible. Consequently, research is currently focused on determining whether these changes can be prevented or modified by early diagnosis, avoidance of factors that contribute to asthma severity, and pharmacologic therapy directed at suppressing airway inflammation.

Establishing the relationship between the pathologic changes and the clinical features of asthma has been difficult. Fiberoptic bronchoscopy with lavage and biopsy provide new insight into mechanisms of airway disease and features that link altered lung function to a specific type of mucosal inflammation (Laitinen et al. 1985; Beasley et al. 1989; Jeffery et al. 1989). From such studies, evidence has emerged that mast cells, eosinophils, epithelial cells, macrophages, and activated T cells are key features of the inflammatory process of asthma (Djukanovic et al. 1990), as illustrated in figure 2. These cells can influence airway function through secretion of preformed and newly synthesized mediators that act either directly on the airway or indirectly through neural mechanisms (Emanuel and Howarth 1995). Furthermore, with the use of cellular and molecular biological techniques, subpopulations of T lymphocytes (TH2) have been identified as important cells that may regulate allergic inflammation in the airway through the release of selective cytokines and also establish disease chronicity (Robinson et al. 1992). In addition, constituent cells of the airway, including fibroblasts, endothelial cells, and epithelial cells, also contribute to this process by releasing cytokines and chemokines.

Figure 2 Cellular Mechanisms Involved in Airway Inflammation

The above factors may be important in both initiating and maintaining the level of airway inflammation (Robinson et al. 1993). It is hypothesized that airway inflammation can be acute, subacute, and chronic. The acute inflammatory response is represented by the early recruitment of cells to the airway. In the subacute phase, recruited and resident cells are activated to cause a more persistent pattern of inflammation. Chronic inflammation is characterized by a persistent level of cell damage and an ongoing repair process, changes that may cause permanent abnormalities in the airway.

Finally, it is recognized that specific adhesion proteins, found in the vascular tissue, lung matrix, and bronchial epithelium, may be critical in directing and anchoring cells in the airway, thus causing the inflammatory changes noted (Albelda 1991). From these studies of the histological features associated with asthma has come evidence of an association between airway inflammation and markers of airway disease severity and an indication that this process is multicellular, redundant, and self-amplifying.

Cell-derived mediators can influence airway smooth muscle tone, modulate vascular permeability, activate neurons, stimulate mucus secretion, and produce characteristic structural changes in the airway (Horwitz and Busse 1995). These mediators can target ciliated airway epithelium to cause injury or disruption. As a consequence, epithelial cells and myofibroblasts—present beneath the epithelium—proliferate and begin to deposit interstitial collagens in the lamina reticularis of the basement membrane. This may explain apparent basement membrane thickening and the irreversible airway changes that may occur in some asthma patients (Roche 1991). Other changes, including hypertrophy and hyperplasia of airway smooth muscle, increases in goblet cell number, enlargement of submucous glands, and remodeling of the airway connective tissue, are components of asthma that need to be recognized in both its pathogenesis and treatment. This inflammatory process is redundant in its ability to alter airway physiology and architecture.

### Child-Onset Asthma

Asthma often begins in childhood, and when it does, it is frequently found in association with atopy, which is the genetic susceptibility to produce IgE directed toward common environmental allergens, including house-dust mites, animal proteins, and fungi (Larsen 1992). With the production of IgE antibodies, mast cells and possibly other airway cells (e.g., lymphocytes) are sensitized and become activated when they encounter specific antigens. Although atopy has been found in 30 to 50 percent of the general population, it is frequently found in the absence of asthma. Nevertheless, atopy is one of the strongest predisposing factors in the development of asthma (Sporik et al. 1990). Furthermore, among infants and young children who have wheezing with viral infections, allergy or family history of allergy is the factor that is most strongly associated with continuing asthma through childhood (Martinez et al. 1995).

### Adult-Onset Asthma

Although asthma begins most frequently in childhood and adolescence, it can develop at anytime in life. Adult-onset asthma can occur in a variety of situations. In adult-onset asthma, allergens may continue to play an important role. However, in some adults who develop asthma, IgE antibodies to allergens or a family history of asthma are not detected. These individuals often have coexisting sinusitis, nasal polyps, and sensitivity to aspirin or related nonsteroidal anti-inflammatory drugs. The mechanisms of nonallergic, or intrinsic, asthma are less well established, although the inflammatory process is similar (but not identical) to that seen in atopic asthma (Walker et al. 1992).

Occupational exposure to workplace materials (animal products; biological enzymes; plastic resin; wood dusts, particularly cedar; and metals) (see component 2) can cause airway inflammation, bronchial hyperresponsiveness, and clinical signs of asthma (Chan-Yeung and Malo 1994; Fabbri et al. 1994). Identification of the causative agent and its removal from the workplace can reduce symptoms; however, some individuals will have persistent asthma even though exposure to the causative agent is eliminated. The mechanisms of this form of asthma are not clearly established.

## Relationship of Airway Inflammation and Lung Function

### Airway Hyperresponsiveness

An important feature of asthma is an exaggerated bronchoconstrictor response to a wide variety of stimuli. The propensity for airways to narrow too easily and too much is a major, but not necessarily unique, feature of asthma. Airway hyperresponsiveness leads to clinical symptoms of wheezing and dyspnea after exposure to allergens, environmental irritants, viral infections, cold air, or exercise. Research indicates that airway hyperresponsiveness is important in the pathogenesis of asthma and that the level of airway responsiveness usually correlates with the clinical severity of asthma.

Airway hyperresponsiveness can be measured by inhalation challenge testing with methacholine or histamine, as well as after exposure to such nonpharmacologic stimuli as hyperventilation with cold dry air, inhalation of hypotonic or hypertonic aerosols, or after exercise (O'Connor et al. 1989). In addition, variability between morning and evening peak expiratory flow (PEF) appears to reflect airway hyperresponsiveness and may serve as a measure of airway hyperresponsiveness, asthma instability, or asthma severity.

The factors contributing to airway inflammation in asthma are multiple and involve a variety of different inflammatory cells (as illustrated in figure 2) (Busse et al. 1993). It is also apparent that asthma is not caused by either a single cell or a single inflammatory mediator but rather results from complex interactions among inflammatory cells, mediators, and other cells and tissues resident in airways. An initial trigger in asthma may be the release of inflammatory mediators from bronchial mast cells, macrophages, T lymphocytes, and epithelial cells. These substances direct the migration and activation of other inflammatory cells, such as eosinophils and neutrophils, to the airway where they cause injury, such as alterations in epithelial integrity, abnormalities in autonomic neural control of airway tone, mucus hypersecretion, change in mucociliary function, and increased airway smooth muscle responsiveness.

The importance of the airway inflammatory response to airway hyperresponsiveness is substantiated by several observations. First, airway markers of inflammation correlate with bronchial hyperresponsiveness. Second, treatment of asthma and modification of airway inflammatory markers not only reduce symptoms but also diminish airway responsiveness. However, the relationship between airway inflammation and airway responsiveness is complex. Some investigations have shown that although anti-inflammatory therapy reduced airway hyperresponsiveness, it did not eradicate it. A small study found that control of airway inflammation did not control bronchial hyperresponsiveness (Lundgren et al. 1988). Thus, factors in addition to inflammation may contribute to airway hyperresponsiveness.

### Airflow Obstruction

Airflow limitation in asthma is recurrent and caused by a variety of changes in the airway. These include:

- Acute bronchoconstriction. Allergen-induced acute bronchoconstriction results from an IgE-dependent release of mediators from the mast cell that include histamine, tryptase, leukotrienes, and prostaglandins (Marshall and Bienenstock 1994), which directly contract airway smooth muscle. Aspirin and other nonsteroidal anti-inflammatory drugs (see component 2) can also cause acute airflow obstruction in some patients, and evidence indicates that this non-IgE-dependent response also involves mediator release from airway cells (Fischer et al. 1994). In addition, other stimuli, including exercise, cold air, and irritants, can cause acute airflow obstruction. The mechanisms regulating the airway response to these factors are less well defined, but the intensity of the response appears related to underlying airway inflammation (Busse et al. 1993). There is emerging evidence that stress can play a role in precipitating asthma exacerbations. The mechanisms involved have yet to be established and may include enhanced generation of proinflammatory cytokines (Friedman et al. 1994).
- Airway edema. Airway wall edema, even without smooth muscle contraction or bronchoconstriction, limits airflow in asthma. Increased microvascular permeability and leakage caused by released mediators also contribute to mucosal thickening and swelling of the airway. As a consequence, swelling of the airway wall causes the airway to become more rigid and interferes with airflow.
- Chronic mucus plug formation. In severe intractable asthma, airflow limitation is often persistent. In part, this change may arise as a consequence of mucus secretion and the formation of inspissated mucus plugs.
- Airway remodeling. In some patients with asthma, airflow limitation may be only partially reversible. The etiology of this component is not as well studied as other features of asthma but may relate to structural changes in the airway matrix that may accompany longstanding and severe airway inflammation. There is evidence that a histological feature of asthma in some patients is an alteration in the amount and composition of the extracellular matrix in the airway wall (Djukanovic et al. 1990; Laitinen and Laitinen 1994). As a consequence of these changes, airway obstruction may be persistent and not responsive to treatment. Regulation of this repair and remodeling process is not well established, but both the process of repair and its regulation are likely to be key events in explaining the persistent nature of the disease and limitations to a therapeutic response. Although yet to be fully explored, the importance of airway remodeling and the development of persistent airflow limitation suggest a rationale for early intervention with anti-inflammatory therapy.

## Relevance of Chronic Airway Inflammation to Asthma Therapy

Although inflammation can be used to describe a variety of conditions in various diseases, the inflammatory response in asthma has special features that include eosinophil infiltration, mast cell degranulation, interstitial airway wall injury, and lymphocyte activation. Furthermore, there is evidence that a TH2 lymphocyte cytokine profile (i.e., IL-4 and IL-5) is instrumental in initiating and sustaining the inflammatory process (James and Kay 1995; Ricci et al. 1993) (see figure 2). These observations also have become important in directing treatment in asthma. It is hypothesized that inflammation is an early and persistent component of asthma. As a consequence, therapy to suppress the inflammation must be long term. Furthermore, preliminary evidence suggests that early intervention with anti-inflammatory therapy may modify the disease process (Agertoft and Pedersen 1994; Laitinen et al. 1992; Djukanovic et al. 1992).

Observations into the basic mechanisms of asthma have had tremendous impact and influence on therapy. Studies have shown that improvements in asthma control achieved with high doses of inhaled corticosteroids are associated with improvement in markers of airway inflammation (Laitinen et al. 1992; Djukanovic et al. 1992). These observations indicate that a strong link may exist between features of airway inflammation, bronchial hyperresponsiveness, and asthma symptoms and severity. Furthermore, insight into the mechanisms of asthma with airway inflammation and bronchial wall repair has become a driving factor in designing logical, and hopefully effective, treatment paradigms.

Another area that needs clarification is the classification of compounds as anti-inflammatory in nature. Because many factors contribute to the inflammatory response in asthma, many drugs may fit this category. At present, corticosteroids are the anti-inflammatory compounds that have been demonstrated to modify histopathological features of asthma (Barnes 1995). It may be necessary to evaluate each new compound for the specificity of its “anti-inflammatory” action and determine from appropriate observations whether the compound is indeed anti-inflammatory and what consequences this has on the clinical features of the disease.

## References

Agertoft L, Pedersen S. Effects of long-term treatment with an inhaled corticosteroid on growth and pulmonary function in asthmatic children. Respir Med. 1994;88:373-81. [pmid: 8036306].
Albelda S M. Endothelial and epithelial cell adhesion molecules. Am J Respir Cell Mol Biol. 1991;4:195-203. [pmid: 2001288].
Barnes P J. Inhaled glucocorticosteroid for asthma. N Engl J Med. 1995;332:868-75. [pmid: 7870143].
Beasley R, Roche W R, Roberts T A, Holgate S T. Cellular events in the bronchi in mild asthma and bronchial provocation. Am Rev Respir Dis. 1989;139:806-17. [pmid: 2923380].
Busse W W, Calhoun W J, Sedgwick J D. Mechanisms of airway inflammation in asthma. Am Rev Respir Dis. 1993;147:S20-S24. [pmid: 8494196].
Chan-Yeung M, Malo J L. Aetiological agents in occupational asthma. Eur Respir J. 1994;7:346-71. [pmid: 8162990].
Djukanovic R, Roche W R, Wilson J W, et al. Mucosal inflammation in asthma. Am Rev Respir Dis. 1990;142:434-57. [pmid: 2200318].
Djukanovic R, Wilson T W, Britten K M, et al. Effect of an inhaled corticosteroid on airway inflammation and symptoms of asthma. Am Rev Respir Dis. 1992;145:669-74. [pmid: 1546849].
Dunnill M S. The pathology of asthma, with special reference to changes in the bronchial mucosa. J Clin Pathol. 1960;13:27-33. [pmid: 13818688].
Emanuel M B, Howarth P H. Asthma and anaphylaxis: a relevant model for chronic disease? An historical analysis of directions in asthma research. Clin Exp Allergy. 1995;25:15-26. [pmid: 7728620].
Fabbri L M, Maestrelli P, Saetta M, Mapp C M. Mechanisms of occupational asthma. Clin Exp Allergy. 1994;24:628-35. [pmid: 7953944].
Fischer A R, Rosenberg M A, Lilly C M, et al. Direct evidence for a role of the mast cell in the nasal response to aspirin in aspirin-sensitive asthma. J Allergy Clin Immunol. 1994;94:1046-56. [pmid: 7798537].
Friedman E M, Coe C L, Ershler W B. Bidirectional effects of interleukin-1 on immune responses in rhesus monkeys. Brain Behav Immunol. 1994;8:87-99.
Horwitz R J, Busse W W. Inflammation and asthma. Clin Chest Med. 1995;16:583-602. [pmid: 8565402].
James D G, Kay A B. Are you TH-1 or TH-2? [editorial]. Clin Exp Allergy. 1995;25:389-90. [pmid: 7553239].
Jeffery P K, Wardlaw A J, Nelson F C, Collins J V, Kay A B. Bronchial biopsies in asthma. An ultrastructural, qualitative study and correlation with hyperreactivity. Am Rev Respir Dis. 1989;140:1745-53. [pmid: 2690708].
Laitinen A, Laitinen L A. Airway morphology: endothelium/basement membrane. Am J Respir Crit Care Med. 1994;150:S14-S17. [pmid: 7952583].
Laitinen L A, Heino M, Laitinen A, Kava T, Haahtela T. Damage of the airway epithelium and bronchial reactivity in patients with asthma. Am Rev Respir Dis. 1985;131:599-606. [pmid: 3994155].
Laitinen L A, Laitinen A, Haahtela T. A comparative study of the effects of an inhaled corticosteroid, budesonide, and a β_2_-agonist, terbutaline, on airway inflammation in newly diagnosed asthma: a randomized, double-blind, parallel-group controlled trial. J Allergy Clin Immunol. 1992;90:32-42. [pmid: 1629507].
Larsen G L. Asthma in children. N Engl J Med. 1992;326:1540-5. [pmid: 1579137].
Lundgren R, Söderberg M, Horstedt P, et al. Morphological studies of bronchial biopsies from asthmatics before and after 10 years of treatment with inhaled steroids. Eur Respir J. 1988;1:883-9. [pmid: 3224689].
Marshall J S, Bienenstock J. The role of mast cells in inflammatory reactions of the airways, skin and intestine. Curr Opin Immunol. 1994;6:853-9. [pmid: 7710709].
Martinez F D, Wright A L, Taussig L M, Holberg C J, Halonen M, Morgan W J. Group Health Medical Associates. Asthma and wheezing in the first six years of life. N Engl J Med. 1995;332:133-8. [pmid: 7800004].
National Heart, Lung, and Blood Institute. Global Initiative for Asthma. National Institutes of Health pub no 95-3659. 1995.
O'Connor G T, Sparrow D, Weiss S T. The role of allergy and nonspecific airway hyperresponsiveness in the pathogenesis of chronic obstructive pulmonary disease. Am Rev Respir Dis. 1989;140:225-52. [pmid: 2665587].
Ricci M, Rossi O, Bertoni M, Matucci A. The importance of TH2-like cells in the pathogenesis of airway allergic inflammation. Clin Exp Allergy. 1993;23:360-9. [pmid: 8334535].
Robinson D S, Durham S R, Kay A B. Cytokines in asthma. Thorax. 1993;48:845-53. [pmid: 8211876].
Robinson D S, Hamid Q, Ying S, et al. Predominant TH2-like broncheoalveolar T-lymphocyte population in atopic asthma. N Engl J Med. 1992;326:298-304. [pmid: 1530827].
Roche W R. Fibroblasts and asthma. Clin Exp Allergy. 1991;21:545-8. [pmid: 1742646].
Sporik R, Holgate S T, Platts-Mills T A, Cogswell J J. Exposure to house-dust mite allergen (Der pI) and the development of asthma in childhood. A prospective study. N Engl J Med. 1990;323:502-7. [pmid: 2377175].
Walker C, Bode E, Boer L, Hausel T T, Blaser K, Virchow J C Jr. Allergic and nonallergic asthmatics have distinct patterns of T-cell activation and cytokine production in peripheral blood and bronchoalveolar lavage. Am Rev Respir Dis. 1992;146:109-15. [pmid: 1626792].