# Pharmacologic Therapy: Managing Asthma Long Term

Key Recommendations for Managing Asthma Long Term
- Persistent asthma is most effectively controlled with daily long-term-control medication, specifically, anti-inflammatory therapy.
- A stepwise approach to pharmacologic therapy is recommended to gain and maintain control of asthma:
  - The amount and frequency of medication is dictated by asthma severity and directed toward suppression of airway inflammation.
  - Therapy should be initiated at a higher level than the patient's step of severity at the onset to establish prompt control and then stepped down.
  - Continual monitoring is essential to ensure that asthma control is achieved.
  - Step-down therapy is essential to identify the minimum medication necessary to maintain control.
- Regular followup visits (at 1- to 6-month intervals) are essential to ensure that control is maintained and the appropriate step down in therapy is considered.
- Therapeutic strategies should be considered in concert with clinician-patient partnership strategies; education of patients is essential for achieving optimal pharmacologic therapy.
- At each step, patients should be advised to avoid or control allergens, irritants, or other factors that make the patient's asthma worse.
- Referral to an asthma specialist for consultation or comanagement of the patient is recommended if there are difficulties achieving or maintaining control of asthma or if the patient requires step 4 care (see component 1-Initial Assessment and Diagnosis). Referral may be considered if the patient requires step 3 care. For infants and young children, referral is recommended if the patient requires step 3 or 4 care and should be considered if the patient requires step 2 care.

## Stepwise Approach for Managing Asthma in Adults and Children Older Than 5 Years of Age

The aim of asthma therapy is to maintain control of asthma with the least amount of medication and hence minimal risk for adverse effects. Control of asthma is defined as:

- Preventing chronic and troublesome symptoms (e.g., coughing or breathlessness in the night, in the early morning, or after exertion)
- Maintaining (near) “normal” pulmonary function
- Maintaining normal activity levels (including exercise and other physical activity)
- Preventing recurrent exacerbations of asthma and minimizing the need for emergency department visits or hospitalizations
- Providing optimal pharmacotherapy with minimal or no adverse effects
- Meeting patients' and families' expectations of and satisfaction with asthma care

The stepwise approach to therapy, in which the dose and number of medications and frequency of administration are increased as necessary and decreased when possible, is used to achieve this control. This is illustrated in figures 7-1 and 7-2. Tables 7-1 and 7-3 present usual medication dosages for therapy. Because asthma is a chronic inflammatory disorder of the airways with recurrent exacerbations, therapy for persistent asthma must emphasize efforts to suppress inflammation over the long term and prevent exacerbations. Recommendations in the stepwise approach to therapy are based on the Expert Panel's review of the literature (see component 3-Medications) and the Expert Panel's experience and opinion.

Figure 7-1 Stepwise Approach for Managing Asthma in Adults and Children Older Than 5 Years of Age

Figure 7-2 Stepwise Approach for Managing Asthma in Adults and Children Older Than 5 Years of Age: Treatment

Table 7-1 Usual Dosages for Long-Term-Control Medications

Medication | Dosage Form | Adult Dose | Child Dose | Comments
Inhaled Corticosteroids(see tables 7-2 and box 7-1)
Systemic Corticosteroids | | | (Applies to all three systemic corticosteroids)
Methylprednisolone | 2, 4, 8, 16, 32 mg tablets | • 7.5–60 mg daily in a single dose or qod as needed for control | • 0.25–2 mg/kg daily in single dose or qod as needed for control | • For long-term treatment of severe persistent asthma, administer single dose in a.m. either daily or on alternate days (alternate-day therapy may produce less adrenal suppression). If daily doses are required, one study suggests improved efficacy and no increase in adrenal suppression when administered at 3:00 p.m. (Beam et al. 1992).
Prednisolone | 5 mg tablets, 5mg/5 cc, 15mg/5 cc | • Short-course “burst”: 40–60 mg per day as single or 2 divided doses for 3–10 days | • Short course “burst”: 1–2 mg/kg/day, maximum 60 mg/day, for 3–10 days | • Short courses or “bursts” are effective for establishing control when initiating therapy or during a period of gradual deterioration.
Prednisone | 1, 2.5, 5, 10, 20, 25 mg tablets; 5 mg/cc, 5 mg/5 cc | | | • The burst should be continued until patient achieves 80% PEP personal best or symptoms resolve. This usually requires 3–10 days but may require longer. There is no evidence that tapering the dose following improvement prevents relapse.
Cromolyn and Nedocromil
Cromolyn | MDI 1 mg/puff | 2–4 puffs tid-qid | 1–2 puffs tid-qid | • One dose prior to exercise or allergen exposure provides effective prophylaxis for 1–2 hours.
| Nebulizer solution 20 mg/ampule | 1 ampule tid-qid | 1 ampule tid-qid
Nedocromil | MDI 1.75 mg/puff | 2–4 puffs bid-qid | 1–2 puffs bid-qid | • See cromolyn above.
Long-Acting Beta_2_-Agonists
Salmeterol | Inhaled
| MDI 21 mcg/puff, 60 or 120 puffs | 2 puffs q 12 hours | 1–2 puffs q 12 hours | • May use one dose nightly for symptoms.
| DPI 50 mcg/ blister | 1 blister q 12 hours | 1 blister q 12 hours | • Should not be used for symptom relief or for exacerbations.
Sustained-Release | Tablet
Albuterol | 4 mg tablet | 4 mg q 12 hours | 0.3–0.6 mg/kg/day, not to exceed 8 mg/day
Methylxanthines
Theophylline | Liquids, sustained-release tablets, and capsules | Starting dose 10 mg/kg/day up to 300 mg max; usual max 800 mg/day | Starting dose 10 mg/kg/day; usual max: | • Adjust dosage to achieve serum concentration of 5– 15 mcg/mL at steady-state (at least 48 hours on same dosage).
| | | • < 1 year of age: 0.2 (age in weeks) + 5 = mg/kg/day | • Due to wide interpatient variability in theophylline metabolic clearance, routine serum theophylline level monitoring is important.
| | | • ≥ 1 year of age: 16 mg/kg/day | • See factors on page 87 that can affect levels.
Leukotriene Modifiers
Zafirlukast | 20 mg tablet | 40 mg daily (1 tablet bid) | | • For zafirlukast, administration with meals decreases bioavailability; take at least 1 hour before or 2 hours after meals.
| 300 mg tablet
Zileuton | 600 mg tablet | 2,400 mg daily (two 300 mg tablets or one 600 mg tablet, qid) | | • For zileuton, monitor hepatic enzymes (ALT).
Factors Affecting Serum Theophylline Concentrations*
Factor | Decreases Theophylline Concentrations | Increases Theophylline Concentrations | | Recommended Action
Food | ↓ or delays absorption of some sustained-release theophylline (SRT) products | ↑ rate of absorption (fatty foods) products | | Select theophylline preparation that is not affected by food.
Diet | ↑ metabolism (high protein) | ↓ metabolism (high carbohydrate) | | Inform patients that major changes in diet are not recommended while taking theophylline.
Systemic, febrile viral illness (e.g., influenza) | | ↓ metabolism | | Decrease theophylline dose according to serum concentration level. Decrease dose by 50 percent if serum concentration measurement is not available.
Hypoxia, cor puimonale, and decompensated congestive heart failure, cirrhosis | | ↓ metabolism | | Decrease dose according to serum concentration level.
Age | ↑ metabolism (1 to 9 years) | ↓ metabolism (<6 months, elderly) | | Adjust dose according to serum concentration level.
Phenobarbital, phenytoin, carbamazepine | ↑ metabolism | | | Increase dose according to serum concenrration level.
Cimetidine | | ↓ metabolism | | Use alternative H_2_ blocker (e.g., famotidine or ranitidine).
Macrolides: TAO, erythromycin, clarithromycin | | ↓ metabolism | | Use alternative antibiotic or adjust theophylline dose.
Quinolones: ciprofloxacin, enoxacin, pefloxacin | | ↓ metabolism | | Use alternative antibiotic or adjust theophylline dose. Citcumvent with ofloxatin if quinolone therapy is required.
Rifampin | ↑ metabolism | | | Increase dose according to serum concentration level.
Ticlopidine | | ↓ metabolism | | Decrease dose according to serum concentration level.
Smoking | ↑ metabolism | | | Advise patient to stop smoking; increase dose according to serum concentration level.

* This list is not all-inclusive; for discussion of other factors, see package inserts.

Table 7-2 Estimated Comparative Daily Dosages for Inhaled Corticosteroids

Adults
Drug | Low Dose | Medium Dose | High Dose
Beclomethasone dipropionate | 168–504 mcg | 504–840 mcg | >840 mcg
42 mcg/puff | (4–12 puffs — 42 mcg) | (12–20 puffs — 42 mcg) | (>20 puffs — 42 mcg)
84 mcg/puff | (2–6 puffs — 84 mcg) | (6–10 puffs — 84 mcg) | (> 10 puffs — 84 mcg)
Budesonide | 200–400 mcg | 400–600 mcg | >600 mcg
DPI: 200 mcg/dose | (1–2 inhalations) | (2–3 inhalations) | (>3 inhalations)
Flunisolide | 500–1,000 mcg | 1,000–2,000 mcg | >2,000 mcg
250 mcg/puff | (2–4 puffs) | (4–8 puffs) | (>8 puffs)
Fluticasone | 88–264 mcg | 264–660 mcg | >660 mcg
MDI: 44, 110, 220 mcg/puff | (2–6 puffs — 44 mcg) OR (2 puffs — 110 mcg) | (2–6 puffs — 110 mcg) | (>6 puffs — 110 mcg) OR (> 3 puffs — 220 mcg)
DPI: 50, 100, 250 mcg/dose | (2–6 inhalations — 50 mcg) | (3–6 inhalations — 100 mcg) | (>6 inhalations — 100 mcg) OR (>2 inhalations — 250 mcg)
Triamcinolone acetonide | 400–1,000 mcg | 1,000–2,000 mcg | >2,000 mcg
100 mcg/puff | (4–10 puffs) | (10–20 puffs) | (>20 puffs)
Children
Drug | Low Dose | Medium Dose | High Dose
Beclomethasone dipropionate | 84–336 mcg | 336–672 mcg | >672 mcg
42 mcg/puff | (2–8 puffs — 42 mcg) | (8–16 puffs — 42 mcg) | (> 16 puffs — 42 mcg)
84 mcg/puff | (1–4 puffs — 84 mcg) | (4–8 puffs — 84 mcg) | (>8 puffs — 84 mcg)
Budesonide | 100–200 mcg | 200–400 mcg | >400 mcg
DPI: 200 mcg/dose | | (1–2 inhalations — 200 mcg) | (>2 inhalations — 200 mcg)
Flunisolide | 500–750 mcg | 1,000–1,250 mcg | > 1,250 mcg
250 mcg/puff | (2–3 puffs) | (4–5 puffs) | (>5 puffs)
Fluticasone | 88–176 mcg | 176–440 mcg | >440 mcg
MDI: 44, 110, 220 mcg/puff | (2–4 puffs — 44 mcg) | (4–10 puffs — 44 mcg) OR (2–4 puffs— 110 mcg) | (>4 puffs — 110 mcg) OR (> 2 puffs — 220 mcg)
DPI: 50, 100, 250 mcg/dose | (2–4 inhalations — 50 mcg) | (2–4 inhalations — 100 mcg) | (>4 inhalations — 100 mcg) OR (>2 inhalations — 250 mcg)
Triamcinolone acetonide | 400–800 mcg | 800–1,200 mcg | > 1,200 mcg
100 mcg/puff | (4–8 puffs) | (8–12 puffs) | (> 12 puffs)
NOTE:
• The most important determinant of appropriate dosing is the clinician's judgment of the patient's response to therapy. The clinician must monitor the patient's response on several clinical parameters and adjust the dose accordingly. The stepwise approach to therapy emphasizes that once control of asthma is achieved, the dose of medication should be carefully titrated to the minimum dose required to maintain control, thus reducing the potential for adverse effect.
• See box 7-1 for an explanation of the rationale used for the comparative dosages. The reference point for the range in the dosages for children is data on the safety of inhaled corticosteroids in children, which, in general, suggest that the dose ranges are equivalent to beclomethasone dipropionate 200–400 mcg/day (low dose), 400–800 mcg/day (medium dose), and >800 mcg/day (high dose).
• Some dosages may be outside package labeling.
• Metered-dose inhaler (MDI) dosages are expressed as the actuator dose (the amount of drug leaving the actuator and delivered to the patient), which is the labeling required in the United States. This is different from the dosage expressed as the valve dose (the amount of drug leaving the valve, all of which is not available to the patient), which is used in many European countries and in some of the scientific literature. Dry powder inhaler (DPI) doses are expressed as the amount of drug in the inhaler following activation.

Box 7-1 Estimated Clinical Comparability of Doses for Inhaled Corticosteroids

Data from in vitro and clinical trials suggest that the different inhaled corticosteroid preparations are not equivalent on a per puff or microgram basis. However, it is not entirely clear what implications these differences have for dosing recommendations in clinical practice because there are few data directly comparing the preparations. Relative dosing for clinical comparability is affected by differences in topical potency, clinical effects at different doses, delivery device, and bioavailability. The Expert Panel developed recommended dose ranges (see table 7-2) for different preparations based on available data and the following assumptions and cautions about estimating relative doses needed to achieve comparable clinical effect.

- Relative topical potency using human skin blanching
  - The standard test for determining relative topical anti-inflammatory potency is the topical vasoconstriction (MacKenzie skin blanching) test.
  - The MacKenzie topical skin blanching test correlates with binding affinities and binding half-lives for human lung corticosteroid receptors (see table below) (Dahlberg et al. 1984; Högger and Rohdewald 1994).
  - The relationship between relative topical anti-inflammatory effect and clinical comparability in asthma management is not certain. However, recent clinical trials suggest that different in vitro measures of anti-inflammatory effect correlate with clinical efficacy (Barnes and Pedersen 1993; Johnson 1996; Kamada et al. 1996; Ebden et al. 1986; Leblanc et al. 1994; Gustafsson et al. 1993; Lundback et al. 1993; Barnes et al. 1993; Fabbri et al. 1993; Langdon and Capsey 1994; Ayres et al. 1995; Rafferty et al. 1985; Bjorkander et al. 1982; Stiksa et al. 1982; Willey et al. 1982).
- Relative doses to achieve similar clinical effects
  - Clinical effects are evaluated by a number of outcome parameters (e.g., changes in spirometry, peak flow rates, symptom scores, quick-relief beta_2_-agonist use, frequency of exacerbations, airway responsiveness).
  - The daily dose and duration of treatment may affect these outcome parameters differently (e.g., symptoms and peak flow may improve at lower doses and over a shorter treatment time than bronchial reactivity) (van Essen-Zandvliet et al. 1992; Haahtela et al. 1991).
  - Delivery systems influence comparability. For example, the DPI delivery device for budesonide delivers approximately twice the amount of drug to the airway as the MDI, thus enhancing the clinical effect (Thorsson et al. 1994; Agertoft and Pedersen 1993).
  - Individual patients may respond differently to different preparations, as noted by clinical experience.
  Clinical trials comparing effects in reducing symptoms and improving peak expiratory flow demonstrate:
  - BDP and BUD achieved comparable effects at similar microgram doses by MDI (Bjorkander et al. 1982; Ebden et al. 1986; Rafferty et al. 1985).
  - BDP achieved effects similar to twice the dose of TAA on a microgram basis.
  - FP achieved effects similar to twice the dose of BDP and BUD via an MDI on a microgram basis (Gustaffson et al. 1993; Fabbri et al. 1993; Barnes et al. 1993; Dahl et al. 1993; Ayres et al. 1995).
  - BUD by dry powder inhaler achieved effects similar to twice the dose delivered by MDI, thus implying greater bronchial delivery by the delivery device (Thorsson et al. 1994; Agertoft and Pedersen 1993).
- Bioavailability
  Both the relative potency and the relative bioavailability (systemic availability) determine the potential for systemic activity of an inhaled corticosteroid preparation. As illustrated here, the bioavailability of an inhaled corticosteroid is dependent on the absorption of the dose delivered to the lungs and the oral bioavailability of the swallowed portion of the dose received.
  - Absorption of the dose delivered to the lungs:
    - Approximately 10 to 30 percent of the dose from the MDI is delivered to the lungs. This amount varies among preparations and delivery devices.
    - Nearly all of the amount delivered to the lungs is bioavailable.
  - Oral bioavailability of the swallowed portion of the dose received:
    - Approximately 80 percent of the dose from the MDI without a spacer/holding chamber is swallowed.
    - The oral bioavailability of this amount varies:
      Either a high first-pass liver metabolism or the use of a spacer/holding chamber with an MDI can decrease oral bioavailability, thus enhancing safety (Lipworth 1995).
      The approximate oral bioavailability of inhaled corticosteroids has been reported as: BDP 20%; FLU 21%; TAA 10.6%; BUD 11%; FP 1% (Chaplin et al. 1980; Check and Kaliner 1990; Clissold and Heel 1984; Davies 1993; Harding 1990; Heald et al. 1995; Martin et al. 1974; Mollman et al. 1985; Szefler 1991; Wurthwein and Rohdewald 1990).
  Although few clinical trials are available that compare systemic activity among preparations (Kamada et al. 1996), studies have found:
  - As suggested by one cross-over comparison study, BDP, FLU, and TAA appear to have equivalent dose-dependent systemic activity, as measured by 24-hour urinary free cortisol excretion (McCubbin et al. 1995).
  - Inconsistent results comparing BDP and BUD. Some show equivalent systemic activity (Kamada et al. 1996; Prahl 1991; Prahl et al. 1987); others show BUD having slightly less systemic activity than BDP (Barnes and Pedersen 1993; Pedersen and Fuglsang 1988; Bisgaard et al. 1988).
  - FP had greater adrenal suppression at doses of 400 to 2,000 micrograms than BUD in equivalent microgram doses delivered by MDI and accompanied by mouth washing to prevent oral bioavailability (Clark et al. 1996). This confirms that there are differences in microgram potencies among preparations and that absorption through the lung can result in systemic activity.

Medication | Topical Potency (Skin Blanching)* | Corticosteroid Receptor Binding Half-Life | Receptor Binding Affinity
Beclomethasone dipropionate (BDP) | 600 | 7.5hours | 13.5
Budesonide (BUD) | 980 | 5.1 hours | 9.4
Flunisonide(FLU) | 330 | 3.5 hours | 1.8
Fluticasone propionate (FP) | 1,200 | 10.5 hours | 18.0
Triamcinolone acetonide (TAA) | 330 | 3.9 hours | 3.6

* Numbers are assigned in reference to dexamethasone, which has a value of “1” in the MacKenzie test.

Table 7-3 Usual Dosages for Quick-Relief Medications

Medication | Dosage Form | Adult Dose | Child Dose | Comments
Short-Acting Inhaled Beta_2_-Agonists
| MDI
Albuterol | 90 mcg/puff, 200 puffs | 2 puffs 5 minutes prior to exercise | 1–2 puffs 5 minutes prior to exercise | An increasing use or lack or expected effect indicates diminished control of asthma.
Albuterol HFA | 90 mcg/puff, 200 puffs | 2 puffs tid-qid prn | 2 puffs tid-qid prn | Not generally recommended for long-term treatment. Regular use on a daily basis indicates the need for additional long-term-control therapy.
Bitolterol | 370 mcg/puff, 300 puffs | | | Differences in potency exist so that all products are essentially equipotent on a per puff basis.
Pirbuterol | 200 mcg/puff, 400 puffs | | | May double usual dose for mild exacerbations.
Terbutaline | 200 mcg/puff, 300 puffs | | | Nonselective agents (i.e., epinephrine, isoproterenol, metaprotetenol) are not recommended due to their potential for excessivecardiac stimulation, especially in high doses.
| DPI
Albuterol Rotahaler | 200 mcg/capsule | 1–2 capsules q 4–6 hours as needed and prior to exercise | 1 capsule q 4–6 hours as needed and prior to exercise
| Nebulizer solution
Albuterol | 5 mg/mL (0.5%) | 1.25–5 mg(.25–1 cc) in 2–3 cc of saline q 4–8 hours | 0.05 mg/kg(min 1.25 mg, max 2.5 mg) in 2–3 cc of saline q 4–6 hours | May mix with cromolyn or ipratropium nebulizer solutions. May double dose for mild exacerbations.
Bitolterol | 2 mg/mL (0.2%) | 0.5–3.5mg (.25–1 cc) in 2–3 cc of saline q 4–8 hours | Not established | May not mix with other nebulizer solutions.
Anticholinergics
| MDI
Ipratropium | 18 mcg/puff, 200 puffs | 2–3 puffs q 6 hours | 1–2 puffs q 6 hours | Evidence is lacking for anticholinetgics producing added benefit to beta_2_-agonists in long-term asthma therapy.
| Nebulizer solution
| .25 mg/mL (0.025%) | 0.25 mg q 6 hours | 0.25–0.5 mg q 6 hours
Systemic Corticosteroids | | (Applies to all three systemic Corticosteroids)
Methylprednisolone | 2, 4, 8, 16, 32 mg tablets | Short course “burst”: 40–60 mg/day as single or 2 divided doses for 3–10 days | Short course “burst”: 1–2 mg/kg/day, maximum 60 mg/day, for 3–10 days | Short courses or “bursts” are effective for establishing control when initiating therapy or during a period of gradual deterioration.
Prednisolone | 5 mg tabs, 5 mg/5 cc, 15 mg/5 cc | | | The burst should be continued until patient achieves 80% PEF personal best or symptoms resolve. This usually requires 3–10 days but may require longer. There is no evidence that tapering the dose following improvement prevents relapse.
Prednisone | 1, 2.5, 5, 10, 20, 25 mg tabs; 5 mg/cc, 5 mg/5 cc

### Gaining Control of Asthma

The clinician must judge individual patient needs and circumstances to determine at what step to initiate therapy. There are two appropriate approaches to gaining control of asthma:

- Start treatment at the step appropriate to the severity of the patient's disease at the time of evaluation and gradually step up if control is not achieved.
  OR
- At the onset, administer therapy at a level higher than the patient's step of severity to gain rapid control. This can be accomplished by either a short course of systemic corticosteroids (see table 7-1) along with inhaled corticosteroids or initiating a medium-to-high dose of inhaled corticosteroids. Once control is gained, step down the therapy.

The two approaches are illustrated by the solid and broken lines in the following diagram.

Two Approaches to Gaining Control of Asthma: (1) Start With High-Dose Therapy and Step Down or (2) Gradually Step Up Therapy

The more aggressive approach of gaining prompt control with a higher level of therapy is preferred, in the opinion of the Expert Panel. At present, there are no studies directly comparing the two approaches—the traditional step-up care (low dose to high) vs. step-down care (initial high dose to low). However, there is evidence supporting a more aggressive initial approach. First, asthma symptoms and altered pulmonary function are related to the level of ongoing airway inflammation. Suppression of airway inflammation is more likely to occur with higher doses of corticosteroids. Furthermore, studies indicate that the dose of inhaled or systemic corticosteroids can be reduced and the clinical benefits sustained once the disease is controlled (Haahtela et al. 1994; Agertoft and Pedersen 1994). A preliminary observation in a retrospective study of children suggests that initiating inhaled corticosteroids early in the course of the disease results in better clinical benefit and less accumulated corticosteroid dose over the long term (Agertoft and Pedersen 1994). Therefore, it is conceivable that a more aggressive approach in initial therapy will more rapidly suppress airway inflammation, restore pulmonary function, and allow for eventual asthma control at lower doses of anti-inflammatory therapy.

Continual monitoring is essential to ensure that asthma control is achieved. Control is indicated by, for example, peak expiratory flow (PEF) values indicating less than 10 to 20 percent variability or PEF consistently greater than 80 percent of the patient's personal best, minimal symptoms, minimal need for short-acting inhaled beta_2_-agonist, absence of nighttime awakenings, and no activity limitations.

If control is not achieved with initial therapy (e.g., within 1 month), the pharmacologic management plan, and possibly the diagnosis, should be reevaluated (see Pharmacologic Steps, page 87).

### Maintaining Control of Asthma

Once control is achieved and sustained for several weeks or months, a reduction in pharmacologic therapy—a step down—is appropriate and helpful to identify the minimum therapy for maintaining control. Reduction in therapy should be gradual because asthma can deteriorate at a highly variable rate and intensity.

In general, the last medication added to the medical regimen should be the first medication reduced. Although guidelines for the rate of reduction and intervals for evaluation have not been established, the opinion of the Expert Panel is that the dose of inhaled corticosteroids may be reduced about 25 percent every 2 to 3 months to the lowest dose possible required to maintain control. It is likely that most patients with persistent asthma will continue to benefit from daily medication to suppress underlying airway inflammation. Patients may relapse when inhaled corticosteroids are completely discontinued (Waalkens et al. 1993).

Regular followup visits (at 1- to 6-month intervals) are essential. Clinicians need to assess whether control of asthma has been maintained and if a step down in therapy is appropriate. Clinicians also need to monitor and review the daily self-management and action plans, the medications, and the patient's self-management behaviors (e.g., inhaler and peak flow monitoring techniques, actions to control factors that aggravate their asthma) (see table 9-1).

The Expert Panel recommends referral to an asthma specialist for consultation or comanagement of the patient if: there are difficulties achieving or maintaining control of asthma; immunotherapy is being considered; the patient requires step 4 care (step 3 or 4 care for infants and young children); or the patient has had a life-threatening exacerbation (see component 1-Initial Assessment and Diagnosis). Referral may be considered if a patient requires step 3 care (or step 2 care for infants and young children).

### Pharmacologic Steps

The following recommendations for pharmacologic therapy at different steps of asthma severity (see figures 7-1 and 7-2) are intended to be general guidelines for making therapeutic decisions. They are not intended to be prescriptions for individual treatment. Specific therapy should be tailored to the needs and circumstances of individual patients. Pharmacologic therapy must be accompanied at every step by patient education and measures to control those factors that contribute to the severity of the asthma (see components 2 and 4).

If optimal control of asthma is not achieved and sustained at any step of care (nocturnal symptoms, urgent care visits, or an increased need for short-acting beta _ 2 _ -agonists are key indications that asthma is not optimally controlled), several actions may be considered:

- Patient adherence and technique in using medications correctly should be assessed.
- A temporary increase in anti-inflammatory therapy may be indicated to reestablish control. A deterioration of asthma may be characterized by gradual reduction in PEF (approximately 20 percent), by failure of inhaled bronchodilators to produce a sustained response, by a reduced tolerance to activities or exercise, and by the development of increasing nocturnal symptoms. To regain control of asthma, a short course of oral prednisone (see table 7-1) is often effective. If asthma symptoms do not recur and pulmonary functions remain normal, no additional therapy is necessary. However, if the prednisone burst does not control symptoms, is effective only for a short period of time (e.g., less than 1 to 2 weeks), or is repeated frequently, the patient should be managed according to the next higher step of care.
- Other factors that diminish control may need to be identified and addressed. These factors include the presence of a coexisting condition (e.g., sinusitis), a new or increased exposure to allergens or irritants, patient or family barriers to adequate self-management behaviors, or psychosocial problems. In some cases, alternative diagnoses may need to be considered, such as vocal cord dysfunction.
- A step up to the next higher step of care may be necessary.
- Consultation with an asthma specialist may be indicated (see component 1-Initial Assessment and Diagnosis).

#### Intermittent Asthma

##### Step 1: Mild Intermittent Asthma

Short-acting inhaled beta_2_-agonists taken as needed to treat symptoms are usually sufficient therapy for mild, intermittent asthma. If effective in relieving symptoms and normalizing pulmonary function, intermittent use of short-acting inhaled beta_2_-agonists can continue to be used on an as-needed basis. If significant symptoms reoccur or beta_2_-agonist is required for quick-relief treatment more than two times a week (with the exception of using beta_2_-agonist for exacerbations caused by viral infections and for exercise-induced bronchospasm [EIB]), the patient should be moved to the next step of care.

Patients with intermittent asthma who experience EIB benefit from taking inhaled beta_2_-agonists, cromolyn, or nedocromil shortly before exercise (see Exercise-Induced Bronchospasm, page 100). Cromolyn or nedocromil taken before unavoidable exposure to an aeroallergen known to exacerbate the patient's asthma may be beneficial (Cockcroft and Murdock 1987).

The Expert Panel recommends the following actions for managing exacerbations due to viral respiratory infections, which are especially common in children. If the symptoms are mild, inhaled beta_2_-agonist (every 4 to 6 hours for 24 hours, longer with a physician consult) may be sufficient to control symptoms and improve lung function. If this therapy needs to be repeated more frequently than every 6 weeks, a step up in long-term care is recommended. If the viral respiratory infection provokes a moderate-to-severe exacerbation, a short course of systemic corticosteroids should be considered. For those patients with a history of severe exacerbations with viral respiratory infections, systemic corticosteroids should be initiated at the first sign of the infection.

The Expert Panel recommends that a detailed written action plan be developed for those patients with intermittent asthma who have a history of severe exacerbations (see figure 9-4). Intermittent asthma—infrequent exacerbations separated by periods of no symptoms and normal pulmonary function—is often mild. However, some patients with intermittent asthma experience sudden, severe, and life-threatening exacerbations. It is essential to treat these exacerbations accordingly. The patient's action plan should include indicators of worsening asthma (specific symptoms and PEF measurements), as well as specific recommendations for using beta_2_-agonist rescue therapy, early administration of systemic corticosteroids, and seeking medical care. Furthermore, periodic monitoring (see component 1-Periodic Assessment and Monitoring) of the patient is appropriate to evaluate whether the patient's asthma is indeed intermittent or whether a step up in long-term therapy is warranted.

#### Persistent Asthma

The Expert Panel recommends that patients with persistent asthma, either mild, moderate, or severe, receive daily long-term-control medication. The most effective long-term-control medications are those with anti-inflammatory effects, that is, those that diminish chronic airway inflammation and airway hyperresponsiveness. Evidence from clinical trials supports this recommendation (van Essen-Zandvliet et al. 1992; Kerstjens et al. 1992).

##### Step 2: Mild Persistent Asthma

The main characteristics of step 2 care are as follows:

- Step 2 care long-term-control medication is daily anti-inflammatory medication: either inhaled corticosteroids at a low dose (see table 7-2), cromolyn, or nedocromil. For children, a trial of cromolyn or nedocromil is often the initial long-term therapy due to the safety profiles of these medications.
- Sustained-release theophylline is an alternative, but not preferred, long-term-control medication. It is not preferred because its modest clinical effectiveness (theophylline is primarily a bronchodilator and its anti-inflammatory activity demonstrated thus far is modest) must be balanced against concerns about potential toxicity (see component 3-Medications). Theophylline remains a therapeutic option for certain patients due to expense or need for tablet-form medication.
  Sustained-release theophylline is given to achieve a serum concentration of between 5 and 15 mcg/mL. Periodic theophylline monitoring is necessary to maintain a therapeutic—but not toxic—level.
- Zafirlukast or zileuton may also be considered an alternative long-term-control medication for patients 12 years of age and older, although their position in therapy is not yet fully established. Initial experience in clinical trials and possible patient requirements for tablet-form medication make these new medications a therapeutic option. Further clinical experience and additional data are needed to establish the role of zafirlukast and zileuton in stepwise therapy.
- Quick-relief medication must be available. Inhaled short-acting beta_2_-agonists should be taken as needed to relieve symptoms. The intensity of treatment will depend on the severity of the exacerbation (see component 3-Managing Exacerbations). Use of inhaled short-acting beta_2_-agonists on a daily basis, or increasing use, indicates the need for additional long-term-control therapy.

##### Step 3: Moderate Persistent Asthma

Consultation with an asthma specialist may be considered because the therapeutic options at this juncture pose a number of challenging risk/benefit outcomes. There are at least three options for initiating step 3 therapy.

- Increase inhaled corticosteroids to medium dose. This strategy will benefit many patients. Adverse effects, although infrequent, may arise (see component 3-Medications).
  OR
- Add a long-acting bronchodilator to a low-to-medium dose of inhaled corticosteroids. The long-acting bronchodilator may be either a long-acting inhaled beta_2_-agonist (e.g., salmeterol) (Greening et al. 1994; Woolcock et al. 1996) or sustained-release theophylline (Nassif et al. 1981); although not preferred, long-acting beta_2_-agonist tablets may be considered. This approach has been shown to improve symptom control and may be especially beneficial in patients who have significant nocturnal symptoms. Improved asthma control has been demonstrated with an inhaled long-acting beta_2_-agonist and a medium-dose inhaled corticosteroid compared to a doubled dose of inhaled corticosteroid (Woolcock et al. 1996), but the potential for incorrectly using long-acting inhaled beta_2_-agonists as a quick-relief medication needs to be considered. The approach of adding theophylline has the potential for adverse reactions related to fluctuations in theophylline serum concentrations.
  OR
- Establish control with medium-dose inhaled corticosteroids, then lower the dose (but still within the medium-dose range) and add nedocromil. Nedocromil has a notable safety profile, and some studies (Lal et al. 1993; O'Hickey and Rees 1994; Svendsen and Jorgensen 1991) have shown that it has some, albeit modest, inhaled corticosteroid-sparing effects in adults. Other studies (e.g., Wong et al. 1993) did not demonstrate this. Therefore, this treatment option is not preferred. Furthermore, adding another inhaler into the patient's medication schedule may affect patient adherence. It will also affect the total cost of care.
  If the patient's asthma is not optimally controlled with initial step 3 therapy, and medications are used correctly, additional step 3 therapy is recommended.
- Increase daily long-term-control medications to a high dose of inhaled corticosteroids,
  AND
- Add a long-acting bronchodilator, especially to control nocturnal symptoms. The long-acting bronchodilator can be either long-acting inhaled beta_2_-agonist or sustained-release theophylline. An evening dose of either bronchodilator may alleviate and prevent nocturnal symptoms and thus improve adherence to the overall therapeutic regimen.

##### Step 4: Severe Persistent Asthma

Patients whose asthma is not controlled on high doses of inhaled corticosteroids and the addition of long-acting bronchodilators will also need oral systemic corticosteroids on a regularly scheduled, long-term basis. For patients who require long-term systemic corticosteroids:

- Use the lowest possible dose (single dose daily or on alternate days).
- Monitor patients closely for corticosteroid adverse side effects (see component 3-Medications).
- When control of asthma is achieved, make persistent attempts to reduce systemic corticosteroids. High doses of inhaled corticosteroids are preferable to systemic corticosteroids because inhaled corticosteroids have fewer systemic effects.
- Consultation with an asthma specialist is recommended.

## Special Considerations for Managing Asthma in Different Age Groups

### Infants and Young Children (5 Years of Age and Younger)

Key Recommendations for Managing Asthma in Infants and Young Children

- Diagnosing asthma in infants is often difficult, yet underdiagnosis and undertreatment are key problems in this age group. Thus, a diagnostic trial of inhaled bronchodilators and anti-inflammatory medications may be helpful.
- In general, infants and young children consistently requiring symptomatic treatment more than two times per week should be given daily anti-inflammatory therapy.
- When initiating daily anti-inflammatory therapy, a trial of cromolyn or nedocromil is often given due to the safety profile of these medications.
- Response to therapy should be carefully monitored. Once control of asthma symptoms is established and sustained, a careful step down in therapy should be attempted. If clear benefit is not observed, alternative therapies or diagnoses should be considered.

#### Diagnosis

Several studies show that as many as 50 to 80 percent of children with asthma develop symptoms before their fifth birthday. Diagnosis can be difficult in this age group and has important implications. On the one hand, asthma in early childhood is frequently underdiagnosed (receiving such labels as chronic bronchitis, wheezy bronchitis, recurrent pneumonia, gastroesophageal reflux, and recurrent upper respiratory tract infections), and thus many infants and young children do not receive adequate therapy. On the other hand, not all wheeze and cough are caused by asthma, and caution is needed to avoid giving infants and young children inappropriately prolonged asthma therapy. Episodic or chronic wheeze, cough, and breathlessness also may be seen in other less common conditions, including cystic fibrosis, vascular ring, tracheomalacia, primary immunodeficiency, congenital heart disease, parasitic disease, and foreign body aspiration.

Among children 5 years of age and younger, the most common cause of asthma symptoms is viral respiratory infection. At present, the relative contributions of airway inflammation, bronchial smooth muscle abnormalities, or other structural factors in producing wheeze with acute viral upper respiratory infections are unknown. There appear to be two general patterns of illness in infants and children who have wheezing with acute viral upper respiratory infections: a remission of symptoms in the preschool years and persistence of asthma throughout childhood. There are no clear markers to predict the prognosis for an individual child; however, the factors more strongly associated with continuing asthma are allergy, a family history of allergy or asthma, and perinatal exposure to passive smoke and aeroallergens (Pullan and Hey 1982; Sporik et al. 1991; Martinez et al. 1995; Martinez 1995).

Diagnosis is complicated by the difficulty in obtaining objective measurements of lung function in this age group. Essential elements in the evaluation include the history, symptoms, physical examination, and assessment of quality of life. A therapeutic trial with medications listed in table 7-3 will also aid in the diagnosis.

#### Treatment

Table 7-4 illustrates the Expert Panel's recommendations for a stepwise approach to managing acute and chronic asthma symptoms, regardless of the prognosis for the wheezing infant or young child.

Stepwise Approach for Managing Infants and Young Children (5 Years of Age and Younger) with Acute or Chronic Asthma Symptoms

| Long-Term Control | | Quick Relif
Step 4
Severe Persistent | - Daily anti-inflammatory medicine; - High-dose inhaled corticosteroid with spacer/holding chamber and face mask; - If needed, add systemic corticosteroids 2 mg/kg/day and reduce to lowest daily or alternate-day dose that stabilizes symptoms | | Bronchodilator as needed for symptoms (see step 1) up to 3 times a day
Step 3
Moderate Persistent | - Daily anti-inflammatory medication. Either:; - Medium-dose inhaled corticosteroid with spacer/holding chamber and face mask OR, once control is established:; - Medium-dose inhaled corticosteroid and nedocromil; OR; - Medium-dose inhaled corticosteroid and long-acting bronchodilator (theophylline) | | Bronchodilator as needed for symptoms (see step 1) up to 3 times a day
Step 2
Mild Persistent | - Daily anti-inflammatory medication. Either:; - Cromolyn (nebuilzer is preferred; or MDI) or nedocromil (MDI only); - Infant and young children usually begin with a trial of cromolyn or nedocromil; OR; - Low-dose inhaled corticosteroid with spacer/holding chamber and face mask | | Bronchodilator as needed for symptoms (see step 1)
Step 1
Mild Intermittent | - No daily medication needed. | | - Bronchodilator as needed for symptoms ≤2 times a week. Intensity of treatment will depend upon severity of exacerbation (see components 3-Managing Exacerbations). Either:; - Inhaled short-acting beta_2_-agonist by nebulizer or face mask and spacer/holding chamber; OR; - Oral beta_2_-agonist for symptoms; - With viral respiratory infection; - Bronchodilator q 4–6 hours up to 24 hours (longer with physican consult) but, in general, repeat no more than once every 6 weeks; - Consider systemic corticosteroid if; - Current exacerbation is severe; OR; - Patient has history of previous severe exacerbations
Step down | | Step up
↓Review treatment every 1 to 6 months. If control is sustanied for at least 3 months, a gradual stepwise reduction in treatment may be possible. | | ↑If control is not achieved, consider step up. But first: review patient medication technique, adherence, and environmental control (avoidance of allergens or other preciptant factors).
NOTE:
• The stepwise approach presents guidelines to assist clinical decisionmaking. Asthma is highly variable; clinicians should tailor specific medication plans to the needs and circumstances of individual patients.
• Gain control as quickly as possible; then decrease treatment to the least medication necessary to maintain control. Gaining control may be accomplished by either starting treatment at the step most appropriate to the initial severity of their condition or by starting at a higher level of therapy (e.g., a course of systemic corticosteroids or higher dose of inhaled corticosteroids).
• A rescue course of systemic corticosteroid (prednisolone) may be needed at any time and step.
• In general, use of short-acting beta_2_-agoinst on a daily basis indicates the need for additional long-term-control therapy.
• It is important to remember that there are very few studies on asthma therapy for infants.
• Consultation with an asthma specialist is recommended for patients with moderate or severe persistent asthma in this age group. Consultation should be considered for all patients with mild persistent asthma.

It is the opinion of the Expert Panel that, in general, infants and young children consistently requiring symptomatic treatment more than two times per week should be given daily anti-inflammatory medication.

At present there are few studies of medications in children younger than 3 years of age. A therapeutic trial of anti-inflammatory medications should be monitored carefully. Treatment should be stopped if a clear beneficial effect is not obvious. Although only inhaled corticosteroids have been shown to be effective in long-term clinical studies with infants (Ilangovan et al. 1993; Gleeson and Price 1988; Bisgaard et al. 1990), cromolyn has demonstrated symptom control and reduced airway hyperresponsiveness in a number of pediatric studies (Geller-Bernstein and Sneh 1980; Hilman et al. 1987; Miraglia del Giudice et al. 1982; Shapiro and Konig 1985; Silverman et al. 1972; Bertelsen et al. 1986; Glass et al. 1981). Fewer studies are available on nedocromil, but benefit has been demonstrated (Brogden and Sorkin 1993). Sustained-release theophylline, an alternative long-term-control medication for older children, may have particular risks of adverse side effects in infants, who frequently have febrile illnesses which increase theophylline concentrations. Theophylline should be considered only if serum concentration levels will be carefully monitored.

In deciding when to initiate daily long-term-control therapy, the clinician must weigh the possible long-term effects of inadequately controlled asthma vs. the possible adverse effects of medications given over prolonged periods. A preliminary study suggests that appropriate control of childhood asthma may prevent more serious asthma or irreversible obstruction in later years (Agertoft and Pedersen 1994). There is evidence that anti-inflammatory treatment can reduce morbidity from wheezing in early childhood (Connett et al. 1993). Studies in older children suggest that the potential but small risk of delayed growth from the use of inhaled corticosteroids is balanced by their efficacy (see component 3-Medications). Furthermore, there are options (cromolyn and nedocromil) for initiating anti-inflammatory therapy.

Recommendations for treating infants and young children at different steps of care include:

- The patient's response to therapy should be monitored carefully. When benefits are sustained, a step down in therapy should be attempted. If there are no clear benefits, treatment should be stopped and alternative therapies or diagnoses should be considered.
- Daily long-term-control therapy often begins with cromolyn or nedocromil.
- When inhaled corticosteroids are introduced in step 2 care, doses may range from 100 to 400 mcg/day; this generally translates to a dose of 15 mcg/kg up to 400 mcg/day beclomethasone (Allen and Lemanske 1993). See Table 7-2 and box 7-1 for discussion of equivalency among preparations.
- When step 3 care is required, it is the opinion of the Expert Panel that control should be established promptly with higher doses of inhaled corticosteroid and then therapy should be stepped down after 2 to 3 months to maintain control (Pedersen and Hansen 1995). For some patients, control of asthma may be maintained by using a lower dose of inhaled corticosteroid (e.g., the minimum dose in the medium-dose range) along with the addition of either nedocromil or theophylline. Some, but not all, studies with nedocromil in adults have demonstrated its potential corticosteroid-sparing effect. There are no studies demonstrating this effect with cromolyn. Studies in infants and young children are necessary. Some clinicians prefer gradually increasing medication to establish control—for example, adding nedocromil or theophylline before increasing the dose of inhaled corticosteroid beyond low-dose therapy.
- Exacerbations caused by viral respiratory infections may be intermittent yet severe. Consider systemic corticosteroids if the exacerbation is moderate to severe or at the onset of a viral respiratory infection if the patient has a history of severe exacerbations.
- Consultation with an asthma specialist should be considered for infants and young children requiring step 2 care; consultation is recommended for those requiring step 3 or step 4 care.
- Several delivery devices are available for infants and young children. The dose received may vary considerably among devices and age groups. (See table 6-3 for a summary of therapeutic issues regarding aerosol delivery devices.) The child's caregivers must be instructed in the proper use of appropriately sized face masks, spacers/holding chambers with face masks, and spacers/holding chambers for medication delivery to be effective and efficient. For children younger than 2 years of age, nebulizer therapy may be preferred for administering cromolyn and for high doses of beta_2_- agonists during exacerbations. Children between 3 and 5 years may begin therapy with MDI and spacer/holding chamber alone, but if the desired therapeutic effects are not achieved, they may require a nebulizer or an MDI plus spacer/holding chamber and face mask.

### School-Age Children (Older Than 5 Years of Age) and Adolescents

Key Recommendations for Managing Asthma in School-Age Children and Adolescents

- Pulmonary function testing should use appropriate reference populations. Adolescents compare better to childhood than to adult predicted norms.
- When initiating daily anti-inflammatory therapy for mild-to-moderate persistent asthma, a trial of cromolyn or nedocromil is often given.
- Adolescents (and younger children as appropriate) should be directly involved in establishing goals for therapy and developing their asthma management plans.
- Active participation in physical activities, exercise, and sports should be promoted.
- A written asthma management plan should be prepared for the student's school, including plans to ensure reliable, prompt access to medications.

The pharmacologic management of school-age children and adolescents follows the same basic principles as those for adults, but the special circumstances of growth, school, and social development require special consideration.

#### Assessment

Pulmonary function testing should be performed using comparison data from an appropriate reference population (American Thoracic Society 1991). Adolescents generally compare better to childhood than to adult predicted norms. Testing in a laboratory or clinic specializing in children can result in higher pulmonary function values and more consistent data. Technicians who conduct pulmonary function testing for children should have special training in achieving the best possible effort from young patients.

#### Treatment

For children with mild or moderate persistent asthma, cromolyn or nedocromil are often effective anti-inflammatory therapies and have no known long-term systemic effects. However, for children with severe persistent asthma, and for many children with moderate persistent asthma, cromolyn and nedocromil do not provide adequate control and thus inhaled corticosteroids are necessary for long-term therapy (see figure 7-2.

The Expert Panel recommends that adolescents (and younger children as appropriate) be directly involved in developing their asthma management plans. Adolescents may experience more difficulties than younger children in adhering to a medication plan because they may fail to recognize the danger of poorly controlled asthma (Strunk et al. 1985), they may not accept having a chronic illness, or they may view the plan as infringing upon their emerging independence and adulthood. In teaching adolescents the same asthma self-management techniques expected of adults, the clinician should address adolescent developmental issues such as building a positive self-image and confidence, increasing personal responsibility, and gaining problemsolving skills. To accomplish this, it is often helpful to see the adolescent initially without parents present and to involve the adolescent directly in setting goals for therapy, developing an appropriate treatment plan, and reviewing the effectiveness of the plan at repeated visits. The parents can be brought in at the end of the visit to review the plan together and emphasize the parents' important role in supporting the adolescent's efforts.

#### School Issues

The clinician should prepare a written asthma management plan for the student's school (see figure 9-5) that includes the following information: an action plan for handling exacerbations (including the clinician's recommendation regarding self-administration of medication and plans to ensure prompt, reliable access to medications); recommendations for long-term-control medications and prevention of exercise-induced bronchospasm (EIB), if appropriate; and identification of those factors that make the student's asthma worse so the school may help the student avoid exposure.

It is preferable to schedule daily, long-term medications so that they are not taken at school, even if this results in unequal dosing intervals throughout the day. However, in school districts that have more comprehensive school nurse coverage, children who would benefit from close supervision to promote adherence may be given medications at school. In this way, daily medication can be administered and patient education can be supplemented most days of the week.

Students with asthma often require medication during school to treat acute symptoms or to prevent EIB that may develop during physical education class, school recess, or organized sports. Reliable, prompt access to medication is essential, but it may be difficult because of school rules that preclude the child from carrying medications. The National Asthma Education and Prevention Program and several member organizations have adopted resolutions that endorse allowing students to carry and self-administer medications when the physician and parent consider this appropriate. It may be helpful for some children to have a compressor-driven nebulizer available at the school.

#### Sports

Physical activity at play or in organized sports is an essential part of a child's life, and full participation in physical activities should be encouraged. Many children with asthma experience cough, wheeze, or excessive fatigue when they exercise. Treatment immediately prior to vigorous activity or exercise usually prevents EIB. If symptoms occur during usual play activities, a step up in long-term therapy is warranted. Poor endurance or EIB can be an indication of poorly controlled persistent asthma; appropriate use of long-term-control medication can reduce EIB (see Exercise-Induced Bronchospasm, page 100). Activity should be limited or curtailed only as a last resort.

### Older Adults

Key Recommendations for Managing Asthma in Older Adults

- Chronic bronchitis/emphysema may coexist with asthma. A trial of systemic corticosteroids will determine the presence of reversibility and the extent of therapeutic benefit.
- Asthma medications may aggravate coexisting medical conditions (e.g., cardiac disease, osteoporosis); adjustments in the medication plan may need to be made.
- Be aware of increased potential for adverse drug/disease interaction (e.g., aspirin, beta-blockers).
- Review of patient technique in using medications and devices is essential.

Because of the high prevalence of other obstructive lung disease (e.g., chronic bronchitis, emphysema) among the elderly, it is important to determine the extent of reversible airflow obstruction. Careful evaluation is required because the precise cause of severe airflow obstruction can be difficult to identify in older patients with asthma. A 2- to 3-week trial of therapy with systemic corticosteroids can help detect the presence of significant reversibility of the airway disease. Long-termcontrol asthma medication can then be offered.

Asthma medications may have increased adverse effects in the elderly patient; adjustments in the medication plan may be necessary.

- Airway response to bronchodilators may change with age, although this is not clearly established. Older patients, especially those with preexisting ischemic heart disease, may also be more sensitive to beta_2_-agonist side effects, including tremor and tachycardia. Concomitant use of anticholinergics and beta_2_-agonists may be beneficial to the older patient (Ullah et al. 1981; Barros and Rees 1990; Gross et al. 1989).
- Theophylline clearance is reduced in the elderly patient (Nielsen-Kudsk et al. 1988), causing increased blood levels of theophylline. In addition, age is an independent risk factor for developing life-threatening events from iatrogenic chronic theophylline overdose (patients 75 years of age or older have a 16-fold greater risk of death from theophylline overdose than do 25-year-olds) (Shannon and Lovejoy 1990). The potential for drug interaction—especially with antibiotics and H_2_-histamine antagonists such as cimetidine—is greater because of the increased use of medications in this age group. Theophylline and epinephrine may exacerbate underlying heart conditions.
- Systemic corticosteroids can provoke confusion, agitation, and changes in glucose metabolism.
- A dose-dependent reduction in bone mineral content may be associated with inhaled corticosteroid use, although low or medium doses appear to have no major adverse effect. Elderly patients may be more at risk due to preexisting osteoporosis, changes in estrogen levels that affect calcium utilization, and a sedentary lifestyle. However, the risk of not adequately controlling asthma may unnecessarily limit the patient's mobility and activities. Concurrent treatment with calcium supplements and vitamin D, and estrogen replacement when appropriate, are recommended. At the present time, the optimal approach for identifying patients at risk for accelerated bone loss from high-dose corticosteroid therapy is to conduct bone densitometry when treatment begins and again 6 months later (NHLBI 1996), although the benefits of this approach have not yet been evaluated in clinical trials.

Medications employed for other diseases may exacerbate asthma; adjustments may need to be made. Nonsteroidal anti-inflammatory agents for treating arthritis, nonselective beta-blockers for treating hypertension, or beta-blockers found in some eye drops used to treat glaucoma may exacerbate asthma. See component 2 for more details on drugs that can complicate asthma management.

For more information on asthma in older patients, see NAEPP Working Group Report: Considerations for Diagnosing and Managing Asthma in the Elderly (NHLBI 1996).

## Managing Special Situations in Asthma

### Seasonal Asthma

Some patients experience asthma symptoms only in relationship to certain pollens and molds. Such seasonal asthma should be treated according to the stepwise approach to long-term management of asthma. If the patient has seasonal asthma on a predictable basis, daily, long-term anti-inflammatory therapy (inhaled corticosteroids, cromolyn, or nedocromil) should be initiated prior to the anticipated onset of symptoms and continued through the season.

### Cough Variant Asthma

Cough variant asthma is seen especially in young children. Cough is the principal symptom; because this frequently occurs at night, examinations during the day may be normal. Monitoring of morning and afternoon PEF variability and/or therapeutic trials with anti-inflammatory or bronchodilator medication may be helpful in diagnosis. Once the diagnosis is established, treat according to the stepwise approach to long-term management of asthma.

### Exercise-Induced Bronchospasm

Exercise-induced bronchospasm—which untreated can limit and disrupt otherwise normal lives—should be anticipated in all asthma patients. EIB is a bronchospastic event that is caused by a loss of heat, water, or both from the lung during exercise because of hyperventilation of air that is cooler and dryer than that of the respiratory tree (Anderson 1985; Godfrey 1986; McFadden and Gilbert 1994). EIB usually occurs during or minutes after vigorous activity, reaches its peak 5 to 10 minutes after stopping the activity, and usually resolves in another 20 to 30 minutes.

Exercise may be the only precipitant of asthma symptoms for some patients. These patients should be monitored regularly to ensure that they have no symptoms of asthma or reductions in PEF in the absence of exercise, because EIB is often a marker of inadequate asthma management and responds well to regular anti-inflammatory therapy.

#### Diagnosis

A history of cough, shortness of breath, chest pain or tightness, wheezing, or endurance problems during exercise suggests EIB. An exercise challenge can be used to establish the diagnosis. This can be performed in a formal laboratory setting or as a free-run challenge sufficiently strenuous to increase the baseline heart rate to 80 percent of maximum for 4 to 6 minutes. Alternatively, the patient may simply undertake the task that previously caused the symptoms. A 15 percent decrease in PEF or FEV_1_ (measurements taken before and after exercise at 5-minute intervals for 20 to 30 minutes) is compatible with EIB.

#### Management Strategies

One goal of management is to enable patients to participate in any activity they choose without experiencing asthma symptoms. EIB should not limit either participation or success in vigorous activities. Recommended treatments include:

- Beta_2_-agonists will prevent EIB in more than 80 percent of patients.
  - Short-acting inhaled beta_2_-agonists used shortly before exercise (or as close to exercise as possible) may be helpful for 2 to 3 hours.
  - Salmeterol has been shown to prevent EIB for 10 to 12 hours (Kemp et al. 1994).
- Cromolyn and nedocromil, taken shortly before exercise, are also acceptable for preventing EIB (Tullett et al. 1985; Woolley et al. 1990; Albazzaz et al. 1989; de Benedictis et al. 1995).
- A lengthy warmup period before exercise may benefit patients who can tolerate continuous exercise with minimal symptoms. The warmup may preclude a need for repeated medications.
- Long-term-control therapy, if appropriate. There is evidence that appropriate long-term control of asthma with anti-inflammatory medication will reduce airway responsiveness, and this is associated with a reduction in the frequency and severity of EIB (Vathenen et al. 1991).

Teachers and coaches need to be notified that a child has EIB, should be able to participate in activities, and may need inhaled medication before activity. Individuals involved in competitive athletics need to be aware that their medication use should be disclosed and should adhere to standards set by the U.S. Olympic Committee (Nastasi et al. 1995). The U.S. Olympic Committee's Drug Control Hotline is 1-800-233-0393.

### Surgery and Asthma

Asthma patients are at risk for specific complications during and after surgery: acute bronchoconstriction triggered by intubation, hypoxemia and possible hypercapnia, impaired effectiveness of cough, atelectasis and respiratory infection (Kingston and Hirshman 1984), and latex exposure (Slater 1994; Sussman and Beezhold 1995). The likelihood of these complications depends on the severity of the patient's airway hyperresponsiveness, airflow obstruction, mucus hypersecretions, and latex sensitivity.

### Recommended actions include

- Patients with asthma should have an evaluation before surgery that includes a review of symptoms, medication use (particularly the use of systemic corticosteroids for longer than 2 weeks in the past 6 months), and measurement of pulmonary function.
- If possible, attempts should be made to improve lung function (FEV_1_ or PEF) to their predicted values or their personal best level. A short course of systemic corticosteroids may be necessary to optimize pulmonary function.
- For patients who have received systemic corticosteroids during the past 6 months, give 100 mg hydrocortisone every 8 hours intravenously during the surgical period and reduce dose rapidly within 24 hours following surgery.

### Pregnancy and Asthma

Maintaining sufficient lung function and blood oxygenation to ensure adequate oxygen supply to the fetus is essential. Poorly controlled asthma during pregnancy can result in increased perinatal mortality, increased prematurity, and low birth weight (Nelson and Weber 1988). For most drugs used to treat asthma and rhinitis, with the exception of brompheniramine, epinephrine, and alpha-adrenergic compounds (other than pseudoephedrine), there is little to suggest an increased risk to the fetus (Schatz et al. 1988; Federal Register 1979; Briggs et al. 1986). Other classes of drugs with some possibility of risk to the fetus include decongestants (other than pseudoephedrine), antibiotics (tetracycline, sulfonamides, and ciprofloxacin), live virus vaccines, immunotherapy (if doses are increased), and iodides.

For more information on asthma and pregnancy, see Executive Summary: Management of Asthma During Pregnancy (NHLBI 1992).

### Stress and Asthma

The role of stress and psychological factors in asthma is important but not fully defined. There is emerging evidence that stress can play an important role in precipitating exacerbations of asthma and possibly act as a risk factor for an increase in prevalence of asthma (Busse et al. 1995). The mechanisms involved in this process have yet to be fully established and may involve enhanced generation of proinflammatory cytokines (Friedman et al. 1994). Equally important are psychosocial factors that are associated with poor outcome (e.g., conflict between patients and family and the medical staff, inappropriate asthma self-care, depressive symptoms, behavioral problems, emotional problems, and disregard of perceived asthma symptoms) (Strunk et al. 1985; Strunk 1993; Brush and Mathé 1993).

## References

Agertoft L, Pedersen S. Importance of the inhalation device on the effect of budesonide. Arch Dis Child. 1993;69:130-3. [pmid: 8024295].
Agertoft L, Pedersen S. Effects of long-term treatment with an inhaled corticosteroid on growth and pulmonary function in asthmatic children. Respir Med. 1994;88:373-81. [pmid: 8036306].
Albazzaz M K, Neale M G, Patel K R. Dose-response study of nebulized nedocromil sodium in exercise induced asthma. Thorax. 1989;44:816-9. [pmid: 2556807].
Allen DB, Lemanske RF Jr. The safety of chronic asthma treatments: continuous beta agonist therapy and prolonged inhaled corticosteroids in childhood asthma. In: Middleton E Jr, Reed CE, Ellis EF, Adkinson NF Jr, Yunginger JW, Busse WW, eds. Allergy: Principles and Practice. 4th ed. St. Louis, MO: Mosby Yearbook, 1993. pp. 1–16.
American Thoracic Society. Lung function testing: selection of reference values and interpretive strategies. Am Rev Respir Dis. 1991;144:1202-18. [pmid: 1952453].
Anderson S D. Issues in exercise-induced asthma. J Allergy Clin Immunol. 1985;76:763-72. [pmid: 2999208].
Ayres J G, Bateman E D, Lundback E, Harris T A J. High dose fluticasone propionate, 1 mg daily, versus fluticasone propionate, 2 mg daily, or budesonide, 1.6 mg daily, in patients with chronic severe asthma. Eur Respir J. 1995;8(4):579-86. [pmid: 7664857].
Barnes N C, Marone G, Di Maria G U, Visser S, Utama I, Payne S L. A comparison of fluticasone propionate, 1 mg daily, with beclomethasone dipropionate, 2 mg daily, in the treatment of severe asthma. Eur Respir J. 1993;6:877-85. [pmid: 8339809].
Barnes P J. Inhaled glucocorticoids for asthma. N Engl J Med. 1995;332:868-75. [pmid: 7870143].
Barnes P J, Pedersen S. Efficacy and safety of inhaled corticosteroids in asthma. Am Rev Respir Dis. 1993;148:S1-S26. [pmid: 8214958].
Barros M J, Rees P J. Bronchodilator responses to salbutamol followed by ipratropium bromide in partially reversible airflow obstruction. Respir Med. 1990;84:371-5. [pmid: 2147295].
Beam W R, Weiner D E, Martin R J. Timing of prednisone and alterations of airways inflammation in nocturnal asthma. Am Rev Respir Dis. 1992;146(6):1524-30. [pmid: 1456570].
Bertelsen A, Andersen J B, Busch P, et al. Nebulised sodium cromoglycate in the treatment of wheezy bronchitis: a multicentre double-blind placebo controlled study. Allergy. 1986;41:266-70. [pmid: 3092689].
Bisgaard H, Munck S L, Nielsen J P, Petersen W, Ohlsson S V. Inhaled budesonide for treatment of recurrent wheezing in early childhood. Lancet. 1990;336:649-51. [pmid: 1975851].
Bisgaard H, Nielsen M D, Anderson B, et al. Adrenal function in children with bronchial asthma treated with beclomethasone dipropionate or budesonide. J Allergy Clin Immunol. 1988;81:1088-95. [pmid: 3288682].
Bjorkander J, Formgren N, Johansson S A, Millqvist E. Methodological aspects on clinical trials with inhaled corticosteroids: results of two comparisons between two steroid aerosols in patients with asthma. Eur J Respir Dis. 1982;63(suppl 122):108-17.
Briggs GG, Freeman RK, Yaffe SJ. Drugs in Pregnancy and Lactation: A Reference Guide to Fetal and Neonatal Risk. 2nd ed. Baltimore, MD: Williams & Wilkins, 1986.
Brogden R N, Sorkin E M. Nedocromil sodium. An updated review of its pharmacological properties and therapeutic efficacy in asthma. Drugs. 1993;45:693-715. [pmid: 7686465].
Brush J, Mathé A. Psychiatric aspects. In: Weiss EB, Stein M, eds. Bronchial Asthma. Boston: Little, Brown and Company, 1993. pp. 1121-31.
Busse W W, Kiecolt-Glaser J K, Coe C, Martin R J, Weiss S T, Parker S R. NHLBI workshop summary. Stress and asthma. Am J Respir Crit Care Med. 1995;151:249-52. [pmid: 7812562].
Chaplin M D, Rooks I I, Swenson E W, Cooper W C, Nerenberg C, Chu N I. Flunisolide metabolism and dynamics of a metabolite. Clin Pharmacol Ther. 1980;27:402-13. [pmid: 7357797].
Check W A, Kaliner M A. Pharmacology and pharmacokinetics of topical corticosteroid derivatives used for asthma therapy. Am Rev Respir Dis. 1990;141(suppl):S44-S51. [pmid: 2178513].
Clark D J, Grove A, Cargill R I, Lipworth B J. Comparative adrenal suppression with inhaled budesonide and fluticasone propionate in adult asthmatic patients. Thorax. 1996;51:262-6. [pmid: 8779128].
Clissold S P, Heel R C. Budesonide: a preliminary review of its pharmacodynamic properties and therapeutic efficacy in asthma and rhinitis. Drugs. 1984;28:485-518. [pmid: 6394263].
Cockcroft D W, Murdock K Y. Comparative effects of inhaled salbutamol, sodium cromoglycate, and beclomethasone dipropionate on allergen-induced early asthmatic responses, late asthmatic responses, and increased bronchial responsiveness to histamine. J Allergy Clin Immunol. 1987;79:734-40. [pmid: 3106449].
Connett G J, Warde C, Wooler E, Lenney W. Use of budesonide in severe asthmatics aged 1–3 years. Arch Dis Child. 1993;69:351-5. [pmid: 8215545].
Dahl R, Lundback E, Malo J L, et al. A dose-ranging study of fluticasone propionate in adult patients with moderate asthma. Chest. 1993;104:1352-8. [pmid: 8222787].
Dahlberg E, Thalen A, Brattsand R, et al. Correlation between chemical structure, receptor binding, and biological activity of some novel, highly active, 16 alpha, 17 alpha-acetal-substituted glucocorticoids. Mol Pharmacol. 1984;25:70-8. [pmid: 6708937].
Davies B. A comparison of beclomethasone dipropionate and budesonide in the treatment of asthma. Br J Clin Prac. 1993;47:87-93.
de Benedictis F M, Tuteri G, Pazzelli P, Bertotto A, Bruni L, Vaccaro R. Cromolyn versus nedocromil: duration of action in exercise-induced asthma in children. J Allergy Clin Immunol. 1995;96:510-4. [pmid: 7560663].
Ebden P, Jenkins A, Houston G, Davies B H. Comparison of two high dose corticosteroid aerosol treatments, beclomethasone dipropionate (1500 mcg/day) and budesonide (1600 mcg/day), for chronic asthma. Thorax. 1986;41:869-74. [pmid: 3547757].
Fabbri L, Burge P S, Croonenborgh L, on behalf of an International Study Group, et al. Comparison of fluticasone propionate with beclomethasone dipropionate in moderate to severe asthma treated for one year. Thorax. 1993;48:817-23. [pmid: 8211872].
Federal Register. 21 CFR Parts 201 and 202. 1979;44(124):37434-67.
Friedman E M, Coe C L, Ershler W B. Bidirectional effects of interleukin-1 on immune responses in rhesus monkeys. Brain Behav Immun. 1994;8:87-99. [pmid: 8081023].
Geller-Bernstein C, Sneh N. The management of bronchial asthma in children under the age of 3½ years using Intal (sodium cromoglycate) administered by Spinhaler. Clin Allergy. 1980;10:503-8. [pmid: 6821512].
Glass J, Archer L N, Adams W, Simpson H. Nebulised cromoglycate, theophylline, and placebo in preschool asthmatic children. Arch Dis Child. 1981;56:648-51. [pmid: 6791596].
Gleeson J G, Price J F. Controlled trial of budesonide given by the nebuhaler in preschool children with asthma. BMJ. 1988;297:163-6. [pmid: 3044506].
Godfrey S. Controversies in the pathogenesis of exercise-induced asthma. Eur J Respir Dis. 1986;68:81-8. [pmid: 3516717].
Greening A P, Ind P, Northfield M, Shaw G. Added salmeterol versus higher-dose corticosteroid in asthma patients with symptoms on existing inhaled corticosteroid. Lancet. 1994;344:219-24. [pmid: 7913155].
Gross N J, Petty T L, Friedman M, Skorodin M S, Silvers G W, Donohue J F. Dose response to ipratropium as a nebulized solution in patients with chronic obstructive pulmonary disease. Am Rev Respir Dis. 1989;139:1188-91. [pmid: 2523681].
Gustafsson P, Tsanakas J, Gold M, Primhak R, Radford M, Gillies E. Comparison of the efficacy and safety of inhaled fluticasone 200 mcg/day in mild and moderate asthma. Arch Dis Child. 1993;69:206-11. [pmid: 8215522].
Haahtela T, Jarvinen M, Kava T, et al. Comparison of a beta_2_-agonist, terbutaline, with an inhaled corticosteroid, budesonide, in newly detected asthma. N Engl J Med. 1991;325:388-92. [pmid: 2062329].
Haahtela T, Jarvinen M, Kava T, et al. Effects of reducing or discontinuing inhaled budesonide in patients with mild asthma. N Engl J Med. 1994;331:700-5. [pmid: 8058076].
Harding S M. The human pharmacology of fluticasone propionate. Respir Med. 1990;84(suppl A):25-9. [pmid: 2287792].
Heald D, Argenti D, Jensen B, Vaccaro S. The disposition of 14C triamcinolone acetonide administrated as single oral dose of 100 mci (800mg) to healthy volunteers. Presented at Asthma Theory to Treatment, Chicago, IL, July 15–17, 1995. (data on file Rhône-Poulenc Rorer)
Hilman B C, Bairnsfather L, Washburne W, Vekovius A L. Nebulized cromolyn sodium: safety, efficacy, and role in the management of childhood asthma. Pediatr Allergy Immunol. 1987;1:43-52.
Högger P, Rohdewald P. Binding kinetics of fluticasone propionate to the human glucocorticoid receptor. Steroids. 1994;59:597-602. [pmid: 7878687].
Ilangovan P, Pedersen S, Godfrey S, Nikander K, Noviski N, Warner J O. Treatment of severe steroid dependent preschool asthma with nebulised budesonide suspension. Arch Dis Child. 1993;68:356-9. [pmid: 8466238].
Johnson M. Pharmacodynamics and pharmacokinetics of inhaled glucocorticoids. J Allergy Clin Immunol. 1996;97(1 Pt 2):169-76. [pmid: 8568148].
Kamada A, Szefler S J, Martin R J, et al. and the Asthma Clinical Research Network. Issues in the use of inhaled glucocorticoids. Am J Respir Crit Care Med. 1996;153:1739-48. [pmid: 8665030].
Kemp J P, Dockhorn R J, Busse W W, Bleecker E R, Van As A. Prolonged effect of inhaled salmeterol against exercise-induced bronchospasm. Am J Respir Crit Care Med. 1994;150:1612-5. [pmid: 7952623].
Kerstjens H A M, Brand P L P, Hughes M D, et al. A comparison of bronchodilator therapy with or without inhaled corticosteroid therapy for obstructive airways disease. N Engl J Med. 1992;327:1413-9. [pmid: 1357553].
Kingston H G, Hirshman C A. Perioperative management of the patient with asthma. Anesth Analg. 1984;63:844-55. [pmid: 6380343].
Lal S, Dorow P D, Venho K K, Chatterjee S S. Nedocromil sodium is more effective than cromolyn sodium for the treatment of chronic reversible obstructive airway disease. Chest. 1993;104:438-47. [pmid: 8393398].
Langdon C G, Capsey L J. Fluticasone propionate and budesonide in adult asthmatics: a comparison using dry powder inhaler devices. Br J Clin Res. 1994;5:85-91.
Leblanc P, Mink S, Keistinen T, Saarelainen P A, Ringdal N, Payne S L. A comparison of fluticasone propionate 200 mcg/day with beclomethasone dipropionate 400 mcg/day in adult asthma. Allergy. 1994;49:380-5. [pmid: 8092438].
Lipworth B J. New perspectives on inhaled drug delivery and systemic bioactivity. Thorax. 1995;50:105-10. [pmid: 7701444].
Lundback B, Alexander M, Day J, et al. Evaluation of fluticasone propionate (500 mcg day-1) administered either as dry power inhaler via a Diskhaler inhaler or pressurized inhaler and compared with beclomethasone dipropionate (1000 mcg day-1) administered by pressurized inhaler. Respir Med. 1993;87:609-20. [pmid: 8290745].
Martin L E, Tanner R J N, Clark T H J, Cochrane G M. Absorption and metabolism of orally administered beclomethasone dipropionate. Clin Pharmacol Ther. 1974;15:267-75. [pmid: 4815952].
Martinez F D. Viral infections and the development of asthma. Am J Respir Crit Care Med. 1995;151:1644-7. [pmid: 7735627].
Martinez F D, Wright A L, Taussig L M, Holberg C J, Halonen M, Morgan W J. Group Health Medical Associates. Asthma and wheezing in the first six years of life. N Engl J Med. 1995;332:133-8. [pmid: 7800004].
McCubbin M M, Milavetz G, Grandgeorge S, et al. A bioassay for topical and systemic effect of three inhaled corticosteroids. Clin Pharmacol Ther. 1995;57:455-60. [pmid: 7712675].
McFadden E R Jr, Gilbert I A. Exercise-induced asthma. N Engl J Med. 1994;330:1362-7. [pmid: 8152449].
Miraglia del G, Capristo A, Maiello, Apuzzo G. Nebulized sodium cromoglycate for the treatment of asthma in children under five years of age. Mod Probl Paediat. 1982;21:122-7.
Mollman H, Rohdewald P, Schmidt E W, Salomon V, Derendorf H. Pharmacokinetics of triamcinolone acetonide and its phosphate ester. Eur J Clin Pharmacol. 1985;29:85-9. [pmid: 4054209].
Nassif E G, Weinberger M, Thompson R, Huntley W. The value of maintenance theophylline in steroid-dependent asthma. N Engl J Med. 1981;304:71-5. [pmid: 7003383].
Nastasi K J, Heinly T L, Blaiss M S. Exercise-induced asthma and the athlete. J Asthma. 1995;32:249-57. [pmid: 7629000].
National Heart, Lung, and Blood Institute. NAEPP Working Group Report: Considerations for Diagnosing and Managing Asthma in the Elderly. National Institutes of Health pub no 96-3662. Bethesda, MD, 1996.
National Heart, Lung, and Blood Institute. Executive Summary: Management of Asthma During Pregnancy. National Institutes of Health pub no 92-3279a. Bethesda, MD, 1992.
Nelson HS, Weber RW. Endocrine aspects of allergic diseases. In: Bierman CW, Pearlman DS, eds. Allergic Diseases From Infancy to Adulthood. Philadelphia: WB Saunders, 1988, ch. 15.
Nielsen-Kudsk J E, Mellemkjaer S, Siggaard C, Nielsen C B. Effects of pinacidil on guinea-pig airway smooth muscle contracted by asthma mediators. Eur J Pharmacol. 1988;157:221-6. [pmid: 3224638].
O'Hickey S P, Rees P J. High-dose nedocromil sodium as an addition to inhaled corticosteroids in the treatment of asthma. Respir Med. 1994;88:499-502. [pmid: 7972972].
Pedersen S, Fuglsang G. Urine cortisol excretion in children treated with high doses of inhaled corticosteroids: a comparison of budesonide and beclomethasone. Eur Respir J. 1988;1:433-5. [pmid: 3169214].
Pedersen S, Hansen O R. Budesonide treatment of moderate and severe asthma in children: a dose-response study. J Allergy Clin Immunol. 1995;95:29-33. [pmid: 7822661].
Prahl P. Adrenocortical suppression following treatment with beclomethasone and budesonide. Clin Exp Allergy. 1991;21:145-6. [pmid: 2021872].
Prahl P, Jensen T, Bjerregaard-Andersen H. Adrenocortical function in children on high-dose steroid aerosol therapy. Allergy. 1987;42:541-4. [pmid: 3688377].
Pullan C R, Hey E N. Wheezing, asthma, and pulmonary dysfunction 10 years after infection with respiratory syncytial virus in infancy. BMJ. 1982;284:1665-9. [pmid: 6805648].
Rafferty P, Tucker L G, Frame M H, Fergusson R J, Biggs B A, Crompton G K. Comparison of budesonide and beclomethasone dipropionate in patients with severe chronic asthma: assessment of relative prednisolone-sparing effects. Br J Dis Chest. 1985;79:244-50. [pmid: 3893509].
Schatz M, Zeiger R S, Harden K M, et al. The safety of inhaled beta-agonist bronchodilators during pregnancy. J Allergy Clin Immunol. 1988;82:686-95. [pmid: 3171009].
Shannon M, Lovejoy F H. The influence of age vs peak serum concentration on life-threatening events after chronic theophylline intoxication. Arch Intern Med. 1990;150:2045-8. [pmid: 2222089].
Shapiro G G, Konig P. Cromolyn sodium: a review. Pharmacotherapy. 1985;5:156-70. [pmid: 3927266].
Silverman M, Connolly N M, Balfour-Lynn L, Godfrey S. Long-term trial of disodium cromoglycate and isoprenaline in children with asthma. BMJ. 1972;3:378-81. [pmid: 4627093].
Slater J E. Latex allergy. J Allergy Clin Immunol. 1994;94:139-49. [pmid: 8064066].
Sporik R, Holgate S T, Cogswell J J. Natural history of asthma in childhood—a birth cohort study. Arch Dis Child. 1991;66:1050-3. [pmid: 1929511].
Stiksa G, Glennow C, Johannesson N. An open crossover trial with budesonide and beclomethasone dipropionate in patients with bronchial asthma. Eur J Respir Dis. 1982;63(suppl 122):266-7.
Strunk R C. Death due to asthma. Am Rev Respir Dis. 1993;148:550-2. [pmid: 8368621].
Strunk R C, Mrazek D A, Wolfson-Fuhrman G S, LaBrecque J F. Physiological and psychological characteristics associated with deaths due to asthma in childhood. A case-controlled study. JAMA. 1985;254:1193-8. [pmid: 4021061].
Sussman G L, Beezhold D H. Allergy to latex rubber. Ann Intern Med. 1995;122:43-6. [pmid: 7985895].
Svendsen U G, Jorgensen H. Inhaled nedocromil sodium as additional treatment to high dose inhaled corticosteroids in the management of bronchial asthma. Eur Respir J. 1991;4:992-9. [pmid: 1664346].
Szefler S J. Glucocorticoid therapy for asthma: clinical pharmacology. J Allergy Clin Immunol. 1991;88:147-65. [pmid: 1880315].
Thorsson L, Edsbacker S, Conradson T B. Lung deposition of budesonide from Turbuhaler is twice that from a pressurized metered-dose inhaler P-MDI. Eur Respir J. 1994;7:1839-44. [pmid: 7828694].
Tullett W M, Tan K M, Wall R T, Patel K R. Dose-response effect of sodium cromoglycate pressurized aerosol in exercise induced asthma. Thorax. 1985;40:41-4. [pmid: 3918356].
Ullah M I, Newman G B, Saunders K B. Influence of age on response to ipratropium and salbutamol in asthma. Thorax. 1981;36:523-9. [pmid: 6458920].
van Essen-Zandvliet E E, Hughes M D, Waalkens H J, Duiverman E J, Pocock S J, Kerrebijn K F. Effects of 22 months of treatment with inhaled corticosteroids and/or beta_2_-agonists on lung function, airway responsiveness, and symptoms in children with asthma. Am Rev Respir Dis. 1992;146:547-54. [pmid: 1355640].
Vathenen A S, Knox A J, Wisniewski A, Tattersfield A E. Effect of inhaled budesonide on bronchial reactivity to histamine, exercise, and eucapnic dry air hyperventilation in patients with asthma. Thorax. 1991;46:811-6. [pmid: 1771604].
Waalkens H J, van Essen-Zandvliet E E, Hughes M D, et al. Cessation of long-term treatment with inhaled corticosteroid (budesonide) in children with asthma results in deterioration. Am Rev Respir Dis. 1993;148:1252-7. [pmid: 8239161].
Willey R F, Godden D J, Carmichael J, Preston P, Frame M, Crompton G K. Comparison of twice daily administration of a new corticosteroid budesonide with beclomethasone dipropionate four times daily in the treatment of chronic asthma. Br J Dis Chest. 1982;76:61-8. [pmid: 7037035].
Woolcock A, Lundback B, Ringdal N, Jacques L A. Comparison of addition of salmeterol to inhaled steroids with doubling of the dose of inhaled steroid. Am J Respir Crit Care Med. 1996;153:1481-8. [pmid: 8630590].
Wong C S, Cooper S, Britton J R, Tattersfield A E. Steroid sparing effect of nedocromil sodium in asthmatic patients on high doses of inhaled steroids. Clin Exp Allergy. 1993;23:370-6. [pmid: 8392897].
Woolley M, Anderson S D, Quigley B M. Duration of terbutaline sulfate and cromolyn sodium alone and in combination on exercise-induced asthma. Chest. 1990;97:39-45. [pmid: 2104792].
Wurthwein G, Rohdewald P. Activation of beclomethasone dipropionate by hydrolysis to beclomethasone-17-monopropionate. Biopharm Drug Dispos. 1990;11:381-94. [pmid: 2207292].