# Second Expert Panel on the Management of Asthma

- *Shirley Murphy, M.D., Chair
  * Executive Committee Member
  Professor and Chair
  Department of Pediatrics
  University of New Mexico School of Medicine
  Albuquerque, New Mexico
- Eugene R. Bleecker, M.D.
  Professor of Medicine
  School of Medicine
  University of Maryland
  Baltimore, Maryland
- *Homer Boushey, M.D.
  Chief, Asthma Clinical Research Center
  and Division of Allergy and Immunology
  Professor of Medicine
  Department of Medicine
  University of California at San Francisco
  San Francisco, California
- *A. Sonia Buist, M.D.
  Professor of Medicine and Physiology
  Head, Pulmonary and Critical Care Division
  Oregon Health Sciences University
  Portland, Oregon
- *William Busse, M.D.
  Professor of Medicine
  Medicine/Allergy and Immunology Department
  University of Wisconsin
  Madison, Wisconsin
- Noreen M. Clark, Ph.D.
  Professor and Dean
  University of Michigan School of Public Health
  Ann Arbor, Michigan
- Howard Eigen, M.D.
  Director
  Section of Pulmonology and Intensive Care
  Professor and Associate Chairman for Clinical Affairs
  Department of Pediatrics
  Riley Hospital for Children
  Indianapolis, Indiana
- Jean G. Ford, M.D.
  Chief, Division of Pulmonary Medicine
  Harlem Hospital Center
  Assistant Professor of Medicine and Public Health (Environmental Health Sciences)
  Columbia University
  New York, New York
- *Susan Janson, D.N.Sc., R.N.
  Professor
  Department of Community Health School of Nursing
  University of California, San Francisco
  San Francisco, California
- *H. William Kelly, Pharm.D.
  Professor of Pharmacy and Pediatrics
  College of Pharmacy
  University of New Mexico
  Albuquerque, New Mexico
- Robert F. Lemanske, Jr., M.D.
  Professor of Medicine and Pediatrics
  University of Wisconsin Hospital and Clinics
  Madison, Wisconsin
- Carolyn C. Lopez, M.D.
  Chief, Department of Family Practice
  Cook County Hospital
  Associate Professor, Department of Family Medicine
  Rush Medical College
  Chicago, Illinois
- Fernando Martinez, M.D.
  Associate Professor of Pediatrics
  Director, Respiratory Sciences Center
  University of Arizona Medical Center
  Tucson, Arizona
- *Harold S. Nelson, M.D.
  Senior Staff Physician
  Department of Medicine
  National Jewish Medical and Research Center
  Denver, Colorado
- Richard Nowak, M.D., M.B.A.
  Vice Chairman
  Department of Emergency Medicine
  Henry Ford Hospital
  Detroit, Michigan
- Thomas A.E. Platts-Mills, M.D., Ph.D.
  Director
  UVA Asthma and Allergy Disease Center
  Head, Division of Allergic and Clinical Immunology
  University of Virginia School of Medicine
  Charlottesville, Virginia
- Gail G. Shapiro, M.D.
  Clinical Professor of Pediatrics
  University of Washington School of Medicine
  Seattle, Washington
- Stuart Stoloff, M.D.
  Private Family Practice
  Clinical Associate Professor of Family and Community Medicine
  University of Nevada
  School of Medicine
  Reno, Nevada
- Kevin Weiss, M.D., M.P.H.
  Director
  Center for Health Services Research
  Rush Primary Care Institute
  Chicago, Illinois

Federal Liaison Representatives
- Clive Brown, M.B.B.S., M.P.H.
  Epidemiologist
  Air Pollution and Respiratory Health Branch
  Centers for Disease Control and Prevention
  Atlanta, Georgia
- Peter J. Gergen, M.D.
  (formerly with the National Institute of Allergy and Infectious Diseases)
  Medical Officer
  Center for Primary Care Research
  Agency for Health Care Policy and Research Bethesda, Maryland
- Edward L. Petsonk, M.D.
  Clinical Section Chief
  Clinical Investigations Branch
  Division of Respiratory Disease Studies
  National Institute for Occupational Safety and Health
  Morgantown, West Virginia

National Heart, Lung, and Blood Institute Staff
- Ted Buxton, M.P.H.
  Special Expert
  National Asthma Education and Prevention Program
- Robinson Fulwood, M.S.P.H.
  Coordinator
  National Asthma Education and Prevention Program
- Michele Hindi-Alexander, Ph.D.
  Health Scientist Administrator
  Division of Lung Diseases
- Suzanne S. Hurd, Ph.D.
  Director
  Division of Lung Diseases
- Virginia S. Taggart, M.P.H.
  Health Scientist Administrator
  Division of Lung Diseases

R.O.W. Sciences, Inc., Support Staff
- Ruth Clark
- Cathy Hageman
- Lisa Marcellino
- Maria New
- Donna Selig
- Keith Stanger
- Donna Tharpe
- Sonia Van Putten
- Eileen Zeller, M.P.H.

NATIONAL ASTHMA EDUCATION AND PREVENTION PROGRAM COORDINATING COMMITTEE
- Claude Lenfant, M.D.,Chair
  National Heart, Lung, and Blood Institute
- Lynn A. Bosco, M.D., M.P.H.
  Agency for Health Care Policy and Research
- Nancy J. Sander
  Allergy and Asthma Network/Mothers of
  Asthmatics, Inc.
- Albert L. Sheffer, M.D.
  American Academy of Allergy, Asthma, and
  Immunology
- Gary S. Rachelefsky, M.D.
  American Academy of Pediatrics
- Barbara Senske Heier, PA-C
  American Academy of Physician Assistants
- Thomas J. Kallstrom, R.R.T.
  American Association for Respiratory Care
- Eloise Branche, R.N., C.O.H.N.-S.
  American Association of Occupational
  Health Nurses
- Allan T. Luskin, M.D.
  American College of Allergy, Asthma, and
  Immunology
- Robert A. Barbee, M.D., F.C.C.P.
  American College of Chest Physicians
- Richard M. Nowak, M.D., M.B.A., F.A.C.E.P.
  American College of Emergency Physicians
- Noreen M. Clark, Ph.D.
  American Lung Association
- Paul V. Williams, M.D.
  American Medical Association
- Barbara M. Santamaria, R.N., M.P.H., C.F.N.P.
  American Nurses Association, Inc.
- Dennis M. Williams, Pharm.D.
  American Pharmaceutical Association
- Pamela J. Luna, M.Ed., Dr.P.H.
  American Public Health Association
- Lani S.M. Wheeler, M.D., F.A.A.P., F.A.S.H.A.
  American School Health Association
- Leslie Hendeles, Pharm.D.
  American Society of Health-System Pharmacists
- A. Sonia Buist, M.D.
  American Thoracic Society
- Barbara L. Hager, M.P.H., C.H.E.S.
  Association of State and Territorial Directors
  of Health Promotion and Public Health Education
- Mary E. Worstell, M.P.H.
  Asthma and Allergy Foundation of America
- Mary Vernon, M.D., M.P.H.
  Centers for Disease Control and Prevention
- Vivian Haines, R.N., M.A., S.N.P.
  National Association of School Nurses
- Susan B. Clark, R.N., M.N.
  National Black Nurses Association, Inc.
- Ruth A. Etzel, M.D., Ph.D.
  National Center for Environmental Health
- Kathryn Silbersiepe, M.D., M.S.
  National Center for Health Statistics
- Ruth I. Quartey, M.A., R.R.T.
  NHLBI Ad Hoc Committee on Minority Populations
- Gregory R. Wagner, M.D.
  National Institute for Occupational Safety and Health
- Lawrence J. Prograis, Jr., M.D.
  National Institute of Allergy and Infectious Diseases
- Sheila A. Newton, Ph.D.
  National Institute of Environmental Health Sciences
- Michael Lenoir, M.D.
  National Medical Association
- L. Kay Bartholomew, Ed.D., M.P.H.
  Society for Public Health Education
- Kimberly Green Goldsborough, M.S.
  U.S. Environmental Protection Agency
- John K. Jenkins, M.D.
  U.S. Food and Drug Administration
- Olivia Carter-Pokras, Ph.D.
  U.S. Public Health Service

NATIONAL ASTHMA EDUCATION AND PREVENTION PROGRAM SCIENCE BASE COMMITTEE
- Albert L. Sheffer, M.D., Chair
  Brigham and Women’s Hospital
  Boston, Massachusetts
- A. Sonia Buist, M.D.
  Oregon Health Sciences University
  Portland, Oregon
- William Busse, M.D.
  University of Wisconsin
  Madison, Wisconsin
- Noreen M. Clark, Ph.D.
  University of Michigan
  Ann Arbor, Michigan
- Shirley Murphy, M.D.
  University of New Mexico
  Albuquerque, New Mexico
- Harold S. Nelson, M.D.
  National Jewish Medical and Research Center
  Denver, Colorado
- Kevin Weiss, M.D., M.P.H.
  Rush Primary Care Institute
  Chicago, Illinois

International Science Base Committee
- Romain Pauwels, M.D., Ph.D., Chair
  University Hospital
  Ghent, Belgium
- Jean Bousquet, M.D., Ph.D.
  Hopital Arnaud de Villeneuve
  Montpellier, France
- Timothy J. H. Clark, M.D.
  National Heart and Lung Institute
  London, England
- Leonardo M. Fabbri, M.D.
  University of Ferrara
  Ferrara, Italy
- Stephen T. Holgate, M.D., D.Sc.
  Southampton General Hospital
  Southampton, England
- Martyn R. Partridge, M.D.
  Whipps Cross Hospital
  London, England
- Søren Pedersen, M.D.
  Kolding Hospital
  Kolding, Denmark
- Ann J. Woolcock, A.O., M.D., F.R.A.C.P.
  Royal Prince Alfred Hospital
  Camperdown, New South Wales, Australia