# References

Administration for Strategic Preparedness and Response. “The Medical Reserve Corps.” n.d. https://aspr.hhs.gov/MRC/Pages/index.aspx. Accessed August 12, 2023.
Administration for Strategic Preparedness and Response. “ASPR Awards $50 Million from the American Rescue Plan to Strengthen the Medical Reserve Corps.” June 8, 2023. https://aspr.hhs.gov/newsroom/Pages/MRC-STTRONG-June2023.aspx. Accessed July 28, 2023.
Aggarwal M., Kokorelias K.M., Glazier R.H., Katz A., Shiers-Hanley J.E., and Upshur R.E. G.. “What is the Role of Primary Care in the COVID-19 Vaccine Roll-Out and the Barriers and Facilitators to an Equitable Vaccine Roll-Out? A Rapid Scoping Review of Nine Jurisdictions.” BMJ Open, vol. 13, no. 4, 2023.
Alfonso Y. Natalia, Leider Jonathon P., Beth Resnick, McCullough J. Mac, and Bishai David. “US Public Health Neglected: Flat or Declining Spending Left States Ill Equipped to Respond to COVID-19.” Health Affairs, vol. 40, no. 4, 2021, pp. 664–671.33764801
AmeriCorps. “2023 Public Health AmeriCorps.” n.d. https://americorps.gov/funded-grants/publichealth-americorps. Accessed July 28, 2023.
AmeriCorps. “White House Announces $400 Million for Public Health AmeriCorps.” May 13, 2021. https://americorps.gov/newsroom/press-release/white-house-announces-400-million-public-health-americorps. Accessed July 28, 2023.
Association of State and Territorial Health Officials (ASTHO). “ASTHO Profile of State and Territorial Public Health: Profile Dashboard Technical Notes.” n.d. https://www.astho.org/globalassets/pdf/profile/astho-dashboard-technical-notes.pdf.
Baker Mike, and Ivory Danielle. “Why Public Health Is in Crisis: Threats, Departures, New Laws.” New York Times, October 20, 2021. https://www.nytimes.com/2021/10/18/us/coronavirus-public-health.html.
Bogaert K., Papillon G., Wyche Etheridge K., Plescia M., Gambatese M., Pearsol J.L., and Mason A.. “Seven Years, 3 Surveys, a Changed World: The State Public Health Workforce 2014–2021” Journal of Public Health Management and Practice, vol. 29, suppl. 1, 2023, pp. S14–s21.36223501
Buchdahl H. “Living History: How an Emergency COVID-19 Workforce Was Born.” CDC Foundation blog, n.d. https://www.cdcfoundation.org/stories/living-and-making-history-covid-19-pandemic-surge-staff. Accessed April 6, 2023.
Centers for Disease Control and Prevention (CDC). “Preparedness Field Assignee Program.” n.d. https://www.cdc.gov/orr/readiness/fieldstaff_services/pfa/docs/PFA-Fact-Sheet_Updated-3-2023.pdf.Accessed July 28, 2023.
CDC. “Expanding COVID-19 Vaccine Distribution to Primary Care Providers to Address Disparities in Immunization.” 2021. https://www.cdc.gov/vaccines/covid-19/downloads/Guide-for-Jurisdictions-on-PCP-COVID-19-Vaccination.pdf. Accessed August 10, 2023.
CDC. “CDC Moving Forward Summary Report.” 2022a. https://www.cdc.gov/about/organization/cdcmoving-forward-summary-report.html. Accessed August 10, 2023.
CDC. “ELC Funding Overview.” 2022b. https://www.cdc.gov/elc/funding/index.html. Accessed July 28, 2023.
CDC. “Tribes and Indian Organizations.” https://www.cdc.gov/tribal/tribes-organizationshealth/tribal_groups.html. 2023a. Accessed July 30, 2023.
CDC. “Public Health Infrastructure Grant.” 2023b. https://www.cdc.gov/infrastructure/phig/programoverview.html. Access July 24, 2023.
CDC. “Where do Associates Work?” 2023c. https://www.cdc.gov/phap/meet_associates/assignments.html. Accessed August 31, 2023.
CDC. “Epidemic Intelligence Service, Annual Update.” 2023d. https://www.cdc.gov/eis/about/annualupdate.html. Accessed August 31, 2023.
CDC. “Preparedness Field Assignee Program.” 2023e. https://www.cdc.gov/orr/readiness/fieldstaff_services/pfa/index.htm. Accessed July 28, 2023.
CDC. “Emergency Preparedness Field Staff.” 2023f. https://www.cdc.gov/orr/readiness/fieldstaff_services/index.htm. Accessed July 28, 2023.
CDC. “Public Health AmeriCorps.” 2023g. https://www.cdc.gov/workforce/resources/americorps.html. Accessed July 28, 2023.
CDC. “Partnering for Vaccine Equity: Partner Network Interactive Map.” 2023h. https://www.cdc.gov/vaccines/health-equity/interactive-partner-network-map.html. Accessed August 8, 2023.
CDC. “Grant Overview.” 2023i. https://www.cdc.gov/infrastructure/phig/program-overview.html. Accessed July 28, 2023.
CDC. “Public Health Emergency Preparedness Program and Guidance.” 2023j. https://www.cdc.gov/orr/readiness/phep/index.htm. Accessed July 28, 2023.
CDC Foundation. “CDC Foundation Sets Up Surge Staff for Success.” n.d. https://www.cdcfoundation.org/stories/cdc-foundation-sets-surge-staff-success. July 28, 2023.
CDC Train. “Welcome to CDC Train.” n.d. https://www.train.org/cdctrain/welcome. Accessed July 28, 2023.
Congressional Research Services. “American Rescue Plan Act of 2021 (P.L. 117–2): Public Health, Medical Supply Chain, Health Services, and Related Provisions.” July 2021. https://crsreports.congress.gov/product/pdf/R/R46834. Accessed July 24, 2023.
Davis M., and Evans A.. “Who are the Vaccinators? A Look at the Vaccination Workforce.” Association of State and Territorial Health Officials blog, April 21, 2021. https://www.astho.org/communications/blog/a-look-at-the-vaccination-workforce/.
de Beaumont Foundation. “Staffing Up: Workforce Levels Needed to Provide Basic Public Health Services for All Americans.” 2021a. https://debeaumont.org/wp-content/uploads/2021/10/Staffing-Up-FINAL.pdf. Accessed April 6, 2023.
de Beaumont Foundation and Association of State and Territorial Health Officials. “Public Health Workforce Interest and Needs Survey, 2021 Summary Report: National Governmental Public Health Workforce.” 2021b. https://debeaumont.org/wp-content/uploads/2022/11/National_2021_PH-WINS_Summary_Report.pdf. Accessed April 6, 2023.
de Beaumont Foundation. ”What is PH-WINS?” n.d. https://debeaumont.org/phwins/what-is-phwins/. Accessed July 23, 2023.
U.S. Department of Treasury. “Coronavirus State and Local Fiscal Recovery Funds.” n.d. https://home.treasury.gov/policy-issues/coronavirus/assistance-for-state-local-and-tribal-governments/state-and-local-fiscal-recovery-funds. Accessed July 28, 2023.
U.S. Department of Treasury. “Coronavirus State and Local Fiscal Recovery Funds.” April 2022. https://home.treasury.gov/system/files/136/21.027-SLFRF-2022-Compliance-Supplement.pdf. Accessed August 9, 2023.
Dirlikov E., Fechter-Leggett E., Thorne S.L., Worrell C.M., Smith-Grant J.C., Chang J., Oster A.M., “CDC COVID-19 State, Tribal, Local, and Territorial Response Team. CDC Deployments to State, Tribal, Local, and Territorial Health Departments for COVID-19 Emergency Public Health Response–- United States, January 21-July 25, 2020.” Morbidity and Mortality Weekly Report, vol. 69, no. 39, October 2020.
FEMA. “Transition of National Guard Activations for COVID-19 Response Activities.” n.d. https://www.fema.gov/fact-sheet/transition-national-guard-activations-covid-19-response-activities. Accessed August 9, 2023.
Gebbie G., Merrill J., and Tilson H.. “The Public Health Workforce.” Health Affairs, vol. 21, no. 6, 2002.
U.S. General Services Administration. “GSA Multiple Award Schedule.” 2022. https://www.gsa.gov/buythrough-us/purchasing-programs/gsa-multiple-award-schedule. Accessed July 28, 2023.
Hare Bork R., Robins M., Schaffer K., Leider J.P., and Castrucci B.C.. "Workplace Perceptions and Experiences Related to COVID-19 Response Efforts Among Public Health Workers—Public Health Workforce Interests and Needs Survey, United States, September 2021-January 2022” Morbidity and Mortality Weekly Report, vol. 71, no. 29, 2022, pp. 920–924.35862270
Juliano C., Schaffer K., and Gambatese M.. “Recovery and Resiliency in 29 Big Cities: Results From the 2021 Public Health Workforce Interests and Needs Survey.” Journal of Public Health Management and Practice, vol. 29, suppl. 1, 2023, pp. s22–s34.36223507
Kocsis S.W., Rosler A.R., Marshall J., and Totten A.. “Learning From COVID-19: Reimagining Public-Private Partnerships in Public Health.” Miliken Institute Center for Public Health, 2022. https://milkeninstitute.org/sites/default/files/2022-02/Learning%20from%20COVID%20v2.8.22-2.pdf.
Kumar P., Lurie K., and Parthasarathy R.. “Building the US Public-Health Workforce of the Future.” February 2022. https://www.mckinsey.com/industries/public-and-social-sector/our-insights/building-the-us-public-health-workforce-of-the-future. Accessed April 6, 2023.
Leider J.P., Coronado F., Bogaert K., and Sellers K.. “A Multilevel Workforce Study on Drivers of Turnover and Training Needs in State Health Departments: Do Leadership and Staff Agree” Journal of Public Health Management and Practice, vol. 27, no. 1, 2021, pp. 30–37.32000170
Leider J.P., McCullough J.M., Singh S.R., Sieger A., Robins M., Fisher J.S., Kuehnert P., and Castrucci B.C.. “Staffing Up and Sustaining the Public Health Workforce” Journal of Public Health Management and Practice, vol. 29, no. 3, 2022, e100–e107.36228097
Leider J.P., Yeager V.A., Kirkland C., Krasna H., Hare Bork R., and Resnick B.. “The State of the US Public Health Workforce: Ongoing Challenges and Future Directions” Annual Review of Public Health, vol. 44, 2023, pp. 323–341.
Lorvick J., Hemberg J., and Comfort M.. “Promoting COVID-19 Vaccination Equity.” Harvard Medical School Primary Care Review, March 18, 2021. https://info.primarycare.hms.harvard.edu/review/promoting-covid-19-vaccination-equity.
McCullough J.M., and Robins M.. “The Opportunity Cost of COVID for Public Health Practice: COVID-19 Pandemic Response Work and Lost Foundational Areas of Public Health Work.” Journal of Public Health Management and Practice, vol. 29, no. 1, February 2023.
Medical Reserve Corps. “A Network Created for this Moment: How the Medical Reserve Corps Has Met the Challenges of the COVID-19 Pandemic.” Assistant Secretary for Preparedness and Response, Department of Health and Human Services, 2021. https://www.phe.gov/mrc/Documents/MRC-COVID19-Report-12Apr2021–508.pdf.
Merrill Jacqueline, Btoush R., Gupta M., Gebbie K.. “A history of public health workforce enumeration.” Journal of Public Health Management and Practice, vol. 9, no. 6, 2003.
Michaels I., Pirani S., Fleming M., Arana M.M., D’Angelo E., Dyer-Drobnack C., DiManno M., Ravenhall S., and Gloria C.T.. “Enumeration of the Public Health Workforce in New York State: Workforce Changes in the Wake of COVID-19.” International Journal of Environmental Research and Public Health, vol. 19, no. 20, 2022.
National Association of County and City Health Officials (NACCHO). “2019 National Profile of Local Health Departments.” 2020. https://www.naccho.org/uploads/downloadable-resources/Programs/Public-Health-Infrastructure/NACCHO_2019_Profile_final.pdf. Accessed April 6, 2023.
NACCHO. “Medical Reserve Corps 2020 Operational Readiness Awards Final Report.” August 2021. https://www.naccho.org/uploads/header-images/public-health-preparedness/2020-ORA-Final-Report.pdf. Accessed July 28, 2023.
NACCHO. “2020 Forces of Change: The COVID-19 Edition.” 2022. https://www.naccho.org/uploads/downloadable-resources/2020-Forces-of-Change-The-COVID-19-Edition.pdf. Accessed April 6, 2023.
National Network of Public Health Institutes (NNPHI). “Network Engagement.” 2023. https://nnphi.org/network-engagement/. Accessed July 28, 2023.
Oregon Health Authority. “COVID-19 Funding for Community-Based Organizations.” n.d. https://www.oregon.gov/oha/PH/ABOUT/Pages/Community-Engagement.aspx. Accessed September 20, 2023.
Perling T. “Workforce/Vaccine Initiative Bolsters Health Departments Across the Nation in COVID-19 Response.” CDC Foundation blog, October 14, 2022. https://www.cdcfoundation.org/blog/workforcevaccine-initiative-bolsters-health-departments-across-nation-covid-19-response.
PHNCI. “How to Use the Public Health Workforce Calculator.” n.d. https://phnci.org/transformation/workforce-calculator. Accessed July 30, 2023
Pogreba Brown K., Austhof E., Rosa Hernández A.M., McFadden Caitlyn, Boyd Kylie, Sharma Jayati, Battaglia Sarah, Shilen Alexandra, and Heslin Kelly M.. “Training and Incorporating Students in SARS-CoV-2 Case Investigations and Contact Tracing.” Public Health Reports, vol. 136, no. 2, 2021.
U.S. Public Health Service. “Who we are.” n.d. https://www.usphs.gov/. Accessed September 19, 2023.
Sellers K., Leider J.P., Gould E., Castrucci B.C., Beck A., Bogaert K., Coronado F., “The State of the US Governmental Public Health Workforce, 2014–2017.” American Journal of Public Health, vol. 109, no. 5, 2019.
Sumaya Ciro. “Enumeration and Composition of the Public Health Workforce: Challenges and Strategies.” American Journal of Public Health, vol. 102, no. 2012, pp. 469–474.22390509
Tolchinsky A. “CDC Foundation Advances Overdose Response Strategy with Nationwide Support.” CDC Foundation blog, July 13, 2022. https://www.cdcfoundation.org/pr/2022/overdose-response-strategy-nationwide-support.
Toney D., Pentella M., Blank E., and Becker S.. “Creating a Blueprint for the Future: Lessons Learned from Public Health Laboratories in the COVID-19 Response.” Journal of Public Health Management and Practice, vol. 27, suppl. 1, 2021, s101–s105.33239571
University of Illinois Chicago. “Community-Based Organizations Selected to Create Contact Tracing Corps.” School of Public Health, September 14, 2020. https://publichealth.uic.edu/newsstories/community-based-organizations-selected-to-create-contact-tracing-corps/.
Weber L. “Thousands of Experts Hired to Aid Public Health Departments Are Losing Their Jobs.” Frontline blog, November 2022. https://www.bigcitieshealth.org/public-health-jobs-disappearing/.
Woodard L., Liaw W., Adepoju O.E., Prabhu S., Chae M., Matuk-Villazon O., and Beech B.M.. “Evaluating a Contact Tracing Course: How Universities Can Develop the Public Health Workforce.” Journal of American College Health, 2022.
Yeager V.A., Madsen E.R., and Schaffer K.. “Qualitative Insights from Governmental Public Health Employees About Experiences Serving During the COVID-19 Pandemic, PH WINS 2021.” Journal of Public Health Management and Practice, vol. 29, suppl. 1, 2023, pp. s73–s86.36223502