# Executive Summary

The governmental public health workforce in the United States performs a wide range of essential duties (including activities known as foundational public health services) to improve the health of the communities it serves. During public health emergencies such as the coronavirus disease 2019 (COVID-19) pandemic, people rely on the public health workforce to expand rapidly to respond to emerging threats while maintaining other foundational public health services. Despite its critical role in supporting the health of communities, the governmental public health workforce has been chronically under-resourced; in fact, a study conducted by the de Beaumont Foundation (2021a) estimated that the workforce did not have the capacity to deliver core public health services for more than a decade leading up to the COVID-19 pandemic. Furthermore, the governmental public health workforce has been understudied, in part, because of its complex infrastructure, which spans more than 3,000 state, tribal, local, and territorial (STLT) public health agencies that vary in governance structure, size, population needs, and capabilities. As a result, there is limited visibility into the number and type of staff hired during the COVID-19 pandemic as well as the range of strategies and supports that STLT public health agencies used to surge the public health workforce during the pandemic.

To identify lessons learned from the COVID-19 pandemic, the Office of the Assistant Secretary for Planning and Evaluation contracted with Mathematica to examine (1) the size and composition of the public health workforce at STLT public health agencies before and during the pandemic, (2) strategies and supports used by STLT public health agencies to surge the governmental public health workforce during the pandemic, and (3) lessons learned and recommendations for directing investments in the STLT public health workforce to prepare for future pandemics. Mathematica conducted a targeted literature scan focused on quantitative data on the STLT public health workforce and 27 semistructured key informant interviews with state and local health officials, federal government officials, and other workforce experts involved directly or indirectly in surge staffing. In this white paper, we summarize findings across the literature and interview data.

## Size and composition of the workforce before and during the COVID-19 pandemic

The literature suggests that there were roughly 200,000 state and local public health workers in 2019 and that the workforce was already significantly understaffed and in decline (Kumar et al. 2022). One study estimated that state and local public health agencies needed another 80,000 full-time equivalent positions to provide foundational public health services prior to the pandemic (de Beaumont Foundation 2021b). Beginning in 2020, the COVID-19 pandemic exacerbated the gaps in the STLT public health workforce, although it is not yet clear how the size of the national workforce changed during the pandemic. Many STLT public health agencies hired staff to fill gaps, with one study estimating that local public health agencies hired 53,600 employees from March 2020 to March 2021 (NACCHO 2022). Staff departures also rose, however, with one study estimating that half the state and local public health workforce departed from 2017 to 2021 because of deferred retirement, burnout and mental health challenges, and other job opportunities (Leider et al. 2023). Findings from our key informant interviews supported the literature: most interviewees from STLT public health agencies noted that their agencies increased hiring in the first one-to-two years of the pandemic, but, by 2023, they believed the number of full-time equivalent positions had returned to pre-pandemic levels because of staff departures.

## Surge strategies and supports

STLT public health agencies used a variety of strategies and supports to surge their workforce during the COVID-19 pandemic. Interviewees most frequently discussed the following strategies: working with staffing agencies to hire contract staff, leveraging the CDC Foundation COVID-19 Corps (which placed staff funded through the Foundation in STLT public health agencies), seeking support from Medical Reserve Corps volunteers, and partnering with universities, community-based organizations, and other organizations. Below, we list key themes that emerged during interviews.

- The most effective surge strategies allowed STLT public health agencies to bypass slow hiring processes within their agency to get immediate help from qualified staff and volunteers (for example, CDC Foundation COVID-19 Corps and Medical Reserve Corps).
- It was harder to fill specialized public health and emergency management roles, such as epidemiologists, data analysts, or health communications specialists, than roles that had fewer education and training requirements. Partnerships with universities, the CDC Foundation, and public health institutes (that is, non-profit organizations focused on advancing public health practice), offered effective solutions.
- Small- and medium-sized local health departments did not have access to select strategies and supports for surging the workforce (for example, CDC Foundation COVID-19 Corps and some funding opportunities) that were available to states and large local public health agencies.
- STLT public health agencies recognized a need for a surged workforce with an equity focus, cultural humility, and lived experience, so they leveraged community-based organization partners to fill this need.
- Interviewees felt that strategies to surge the public health workforce during public health emergencies are important, but they should not replace investments in staff who provide foundational public health services.

## Lessons learned and recommendations

Experiences surging the governmental public health workforce during the COVID-19 pandemic highlighted successful strategies and important lessons for future pandemics. It will be critical to explore how to sustain and reactivate these strategies through funding, ongoing partnerships, and coordinated emergency planning at the STLT and national level. It is also important to consider ways to build the baseline governmental public health workforce through pathways into public health (including pipeline programs) and sustained funding, so that STLT public health agencies have the capacity needed to quickly respond and surge the workforce during emergencies. Based on study findings, we identified the following recommendations for federal agencies, STLT public health agencies, and other public health organizations:

For federal agencies:

- Work towards sustainability and plan for future needs of successful national programs such as MRC and contractual support for initiatives such as CDC Foundation’s COVID-19 Corps.
- Consider mechanisms such as funding, technical assistance, and peer learning opportunities to enable public health institutes to effectively provide surge support to STLT public health agencies during emergencies.
- Consider options to support the expansion of pipeline programs, such as the Public Health Associate Program, Career Epidemiology Field Officer program, Preparedness Field Assignee program, and Public Health AmeriCorps, to “build the bench” for the SLTL public health workforce.
- Explore options for providing funding to STLT public health agencies (during public health emergencies and at baseline), focusing on flexible, sustained funding opportunities that make it easier for STLT health agencies to hire staff on a long-term basis and build a career in governmental public health.
- Consider ways to encourage state spending on public health to increase investments in the public health workforce and infrastructure.
- Support improvements in STLT governmental hiring practices through promulgation of best practices and provision of technical assistance to states.
- Support efforts to improve recruitment and retention of a skilled and diverse STLT public health workforce through policies such as student loan repayment.

For STLT public health agencies:

- Establish mechanisms to surge the workforce as part of ongoing emergency preparedness and response planning.
- Continue to leverage partnerships with CBOs, universities, and health systems to help prepare for future pandemics, support ongoing efforts to promote health equity, and expose students to the public health field
- Strengthen partnerships with public health institutes, which provided critical staffing, planning, and training supports to STLT public health agencies.
- Share best practices for recruiting and retaining public health staff, including strategies for promoting long-term career growth and working with other governmental agencies to improve pay and benefits for the public health workforce.

For organizations partnering with public health agencies:

- Continue to study the effectiveness of surge strategies and consider options for improving or scaling up efforts during public health emergencies.
- Develop resources to support emergency preparedness and planning for future pandemics, such as surge planning playbooks and workforce planning tools.
- Seek opportunities to directly engage local public health agencies in surge staffing strategies.
- Pursue additional research enumerating the national public health workforce on a frequent basis.