# IV Lessons Learned and Recommendations

The findings from this study offer valuable insights into surge strategies and supports used during the COVID-19 pandemic but have some important limitations. First, because the study was exploratory, we only conducted 27 key informant interviews. We attempted to identify key informants with diverse perspectives (see Appendix B), but the findings are not exhaustive and are not representative of all public health officials and experts. Both the literature search and key informant interviews included limited data from tribal public health organizations and territorial health departments. Further data collection is needed with these important groups to better understand their experiences surging the workforce during the COVID-19 pandemic. The key informant interview sample also consisted only of leaders from federal and STLT public health agencies and other organizations involved in surging the workforce; it did not include the perspectives of STLT public health workers in non-leadership roles who were reassigned or were hired to surge the workforce during the COVID-19 pandemic. These workers are likely to have insights into the successes and challenges of the surge strategies that were not captured in our data collection efforts. Additionally, interviews were limited to 60 minutes or less. As a result, we were not able to collect detailed data on all surge strategies and supports, such as the role that partnerships played in surging the workforce. Despite these limitations, the recurring themes that emerged during interviews offer a glimpse into successes of surging the workforce during the COVID-19 pandemic and illuminate areas for improvement. Below, we highlight these lessons learned and recommendations.

The STLT public health workforce was understaffed and underfunded leading up to the COVID-19 pandemic, and the pandemic exacerbated these challenges. The pandemic revealed that public health agencies lacked staff working in foundational public health areas, which include preparedness and response, as well as organizational supports such as human resources, finance and procurement, IT, and data management. Interviewees overwhelmingly noted that STLT public health agencies need ongoing funding and resources to hire and retain these critical staff so that they can prepare for and effectively surge the workforce during future public health emergencies.

The pandemic also revealed that most STLT public health agencies did not have a strategy in place for surging the workforce. Inefficient government hiring systems that require multiple levels of approval and extended timelines made it difficult for STLT public health agencies to hire staff quickly. Agencies relied on reassigning their staff for months on end (and, often, in roles that were not aligned with their skill set) until they were able to get contracts and other agreements in place to onboard workers and volunteers. This contributed to burnout and job dissatisfaction for employees and further decreased STLT public health agencies’ capacity to provide foundational public health services. Interviewees highlighted the importance of having an emergency response plan in place at STLT public health agencies, including having agreements with staffing agencies, public health institutes, and other organizations to surge the workforce. Interviewees noted that additional resources, such as surge planning playbooks, could help agencies make emergency preparedness plans. They also suggested that cross-training staff in emergency preparedness—as well as instituting federal requirements for agency staff to be trained in emergency response as part of funding opportunities such as CDC’s PHEP cooperative agreement—would further promote emergency readiness.

Coordinated national efforts to surge the workforce are essential to support STLT public health agencies’ response to future public health emergencies. STLT public health agencies relied on staff and volunteers from national organizations such as CDC Foundation’s COVID-19 Corps and MRC to fill key roles during the COVID-19 pandemic, and interviewees suggested that these programs receive investments to support their expansion and ensure they can be activated quickly for future public health emergencies. A few interviewees noted that STLT public health agencies and organizations directly involved in the COVID-19 pandemic workforce surge should consider maintaining relationships with staff and volunteers who were deployed during the pandemic to support future emergency response efforts.

Many STLT public health agencies leveraged partnerships with CBOs, universities, public health institutes, health systems, and other organizations during the COVID-19 pandemic, presenting promising opportunities for future collaboration. Agencies said these partnerships helped them deliver essential public health services, promote health equity, and train staff and volunteers. STLT public health agencies should consider options for maintaining and expanding these partnerships as they build their foundational capabilities and prepare for future pandemics, and federal agencies should continue to seek opportunities to provide funding and technical assistance to STLT public health agencies in this area. Given the frustration that interviewees expressed about funding flowing to hospitals without recognition of local health departments, future research could explore and share best practices for funding and establishing hospital-public health partnerships, as well as the challenges, successes, and promising strategies for building partnerships between STLT health agencies and other entities to surge the workforce.

STLT public health agencies need flexible ongoing funding so they can fill vacancies and provide foundational public health services, better positioning them to respond to future pandemics. Interviewees emphasized that funding for the public health workforce must be flexible to enable STLT public health agencies to hire staff and invest in priority areas. Flexibility is also critical so staff can pivot to address emerging public health issues. Interviewees appreciated the flexibility of CDC’s Workforce and Infrastructure grant, but they noted the importance of sustainable long-term funding and highlighted fundamental flaws in the current approach to public health funding, which relies on short-term grants and cooperative agreements for specific projects. Specifically, STLT interviewees said that they hire staff for specific grants or cooperative agreements, but, when the funding ends, they need to find new funding streams to retain staff or else let staff go, which is inefficient and deters staff from pursuing long-term careers. Another interviewee said that awarding large sums of time-limited funding to STLT public health agencies at the start of the COVID-19 pandemic was not ideal because agencies did not have time to strategize on the best way to use the funds and were left in a position to spend as quickly as they could. Distributing funding over a longer period of time would have allowed agencies to make sustainable staffing changes. Another interviewee suggested that increases in public health funding should not just fall on the federal government but should instead be shared with states (for example, by establishing federal matching programs like they do for other government programs).

“The biggest challenge and frustration with respect to [federal funding] for public health is, we wait until the emergency is upon us to start throwing money at it. And then, we're scrambling to try to figure out how do we implement these dollars as effectively and efficiently as we can, rather than investing in a system that has the ability to expand and adjust and reassign staff.”

– Interviewee

Agencies and organizations that provide funding or staffing resources should consider ways to directly fund and engage local public health agencies. Nearly all the local public health agencies in the study said that direct federal funding for local public health would be helpful. It might not be feasible for the federal government to manage grants to such a large number of funding recipients, but it could explore options for expanding direct funding opportunities to more jurisdictions, providing direct communication or CDC liaisons to local jurisdictions, or encouraging states to increase transparency about how federal public health funding is distributed. Similarly, medium and small local public health agencies, which were on average the most understaffed leading up to the pandemic, described feeling left out of opportunities such as CDC Foundation staff placements. Organizations that supported the workforce surge could consider options for expanding their reach to more medium- and small-sized local public health agencies in the future.

Looking ahead, the public health field needs to consider ways to attract and retain skilled and diverse talent to support foundational public health services including emergency preparedness and response. With more than half of the STLT public health workforce expected to retire or quit by 2025 if current trends continue (Leider et al. 2023), interviewees said that it is critical to consider new ways to recruit people with important skill sets (such as skills in public health data and informatics) and retain talent. Interviewees noted that higher salaries, reimbursement for continued education, and loan repayments are helpful for retaining staff but difficult to provide because most public health funding is categorical and short-term (which keeps many staff roles tied to specific grants) and there are multiple layers of government involved in approving staff salary. Many interviewees highlighted the importance of pipeline programs such as the Public Health Associate Program and Public Health AmeriCorps and suggested expanding these programs so they can “build the bench” for the STLT public health workforce and infuse public health agencies with new staff on an ongoing basis. Interviewees also described the importance of opportunities for advancement, increased diversity in the workplace, and support for mental health as factors that affect retention.

“A lot of these issues within public health infrastructure [low pay, difficulty competing with private sector] are larger government problems. Most public health departments don’t have the authority to change how much they pay people. But I think it’s indicative of a larger institutional problem in this country. And that’s the work that needs to be done.”

– Interviewee

Interviewees highlighted areas for future research and resource development. Regular national data on the public health workforce is lacking, so many interviewees suggested using funding to enumerate and understand workforce needs on a frequent (for example, annual) basis. One interviewee said that establishing standard occupation codes for public health workers would also support enumeration.

Interviewees also requested guidance for succession planning and workforce planning tools, standardized job descriptions or specifications that could be adapted by STLT public health agencies to recruit staff, and federal guidelines for public health staffing to guide hiring. They also said that more exploration of how centralized, decentralized, or hybrid state public health governance structure influences state and local agencies’ ability to surge the workforce would help in planning and preparing for future pandemics, as state governance structure might affect the types of resources, strategies, and supports available to local agencies.

Recommendations for federal policy, STLT public health agencies, and their partners

Experiences surging the governmental public health workforce during the COVID-19 pandemic highlighted successful strategies and important lessons for future pandemics. It will be critical to explore how to sustain and reactivate these strategies through funding, ongoing partnerships, and coordinated emergency planning at the STLT and national level. It is also important to consider ways to build the baseline governmental public health workforce through pathways into public health (including pipeline programs) and sustained funding, so that STLT public health agencies have the capacity needed to quickly respond and surge the workforce during emergencies. Based on study findings, we identified the following recommendations for federal agencies, STLT public health agencies, and other public health organizations.

### For federal policy

- Work towards sustainability and plan for future needs of national programs such as the Medical Reserve Corps and contractual support for initiatives such as the CDC Foundation's COVID-19 Corps
- Consider mechanisms such as funding, technical assistance, and peer learning opportunities to enable public health institutes to effectively provide surge support to STLT public health agencies during emergencies
- Consider options to support the expansion of pipeline programs, such as the Public Health Associate Program, Career Epidemiology Field Officer program, Preparedness Field Assignee program, and Public Health AmeriCorps, to "build the bench" for the STLT public health workforce
- Explore options for providing funding to STLT public health agencies (during public health emergencies and at baseline) that maximize:
  – Flexible funding opportunities instead of categorical funding with stringent rules
  – Sustained levels of funding to move away from the current cycles of federal funding that make it hard to retain staff
  – Fewer and larger funding opportunities instead of splitting funds across programs, which can be difficult to manage
  – Directly funding a larger number of local public health agencies
- Consider ways to encourage state spending on public health (for example, matching programs)
- Support improvements in STLT governmental hiring practices through promulgation of best practices and provision of technical assistance to states
- Support efforts to improve recruitment and retention of STLT public health staff through policies such as federal student loan repayment

### For STLT public health agencies

- Establish mechanisms to surge the workforce as part of ongoing emergency preparedness and response planning
- Continue leveraging partnerships with CBOs, universities, and health systems to help prepare for future pandemics, support ongoing efforts to promote health equity, and expose students to the public health field
- Strengthen partnerships with public health institutes, which provided critical staffing, planning, and training support to STLT public health agencies
- Share best practices for recruiting and retaining public health staff, including strategies for promoting long-term career growth and working with other governmental agencies to improve pay and benefits for the public health workforce

### For organizations partnering with public health agencies

- Continue to study the effectiveness of surge strategies and consider options for improving or scaling up efforts for future pandemics
- Develop resources to support emergency preparedness and planning for future pandemics, such as surge planning playbooks and workforce planning tools
- Seek opportunities to directly engage local public health agencies in surge staffing strategies
- Pursue additional research enumerating the national public health workforce on a frequent basis

CBOs = community-based organizations; STLT = state, tribal, local, and territorial