# III Strategies and Supports to Surge the Workforce

STLT public health agencies used a variety of strategies and supports to surge the capacity of their workforce during the COVID-19 pandemic. Exhibit III.1 categorizes and lists common surge strategies and supports.

Exhibit III.1 Strategies and supports to surge the STLT public health workforce

CDC = Centers for Disease Control and Prevention; STLT = state, tribal, local, and territorial.

Here, we describe specific strategies (Section III.1) and supports (Section III.2), along with challenges, successes, perceptions of effectiveness, and other insights, and then we summarize findings across strategies and supports (Section III.3). A table summarizing the successes and challenges of each strategy is available in Appendix Exhibit C.1.

## III.1 Surge strategies used during the COVID-19 pandemic

### III.1.A The CDC Foundation COVID-19 Corps

Successes: The CDC Foundation quickly hired and placed highly qualified candidates at no cost to STLT public health agencies.

Challenges: The CDC Foundation COVID-19 Corps staff were often paid higher salaries than STLT public health agency staff, creating some tension. The CDC Foundation generally did not provide direct support to medium and small local public health agencies.

Through a combination of CDC funding and private funding, the CDC Foundation directly hired, managed, and paid staff who were placed in STLT agencies nationwide (either in person or remotely) to support the COVID-19 pandemic response. The CDC Foundation is an independent nonprofit organization created by Congress. It leverages federal grant, philanthropic, and private funding to support CDC’s mission and advance public health (CDC Foundation n.d.). At the outset of the COVID-19 pandemic, the CDC Foundation developed the COVID-19 Corps to place temporary staff in STLT public health agencies at no cost to the public health agency. The CDC Foundation’s COVID-19 pandemic response was based in part on a prior surge staffing effort for the opioid response, during which the CDC Foundation hired 60 public health analysts and deployed them to STLT public health agencies across the US (Tolchinsky 2022). The COVID-19 Corps workforce surge provided similar support on a larger scale, working with 100 STLT public health agencies to fill roughly 4,000 roles including epidemiologists, contact tracers, case investigators, data scientists, communication specialists, public health nurses, program managers, IT specialists, and others (Perling 2022). When temporary contracts ended, many STLT public health agencies continued to use the CDC Foundation as a hiring authority for positions funded by the STLT public health agency.

Many STLT public health agency interviewees had COVID-19 Corps staff at their agencies during the pandemic and shared overwhelmingly positive feedback about the support they received. Interviewees noted that the CDC Foundation was able to hire more quickly than STLT public health agencies because of its competitive pay, benefits, and wide network. STLT public health agency interviewees also appreciated receiving staff at no cost to the public health agency, which reduced challenges with restrictive or limited budgets. Furthermore, the CDC Foundation aimed to recruit staff whose racial, ethnic, and cultural backgrounds aligned with the communities they were going to serve, which improved cultural responsiveness. Many positions were remote, which also allowed the CDC Foundation to recruit people from outside of states and jurisdictions with specialized skills. Because of the success of the program, some STLT public health agencies found ways to permanently hire CDC Foundation staff. A CDC Foundation publication noted that about 20 percent of the temporary staff hired to support the COVID-19 pandemic response stayed on in permanent positions (Buchdahl n.d.).

“CDC Foundation was great at finding really smart people. Even though they were temporary staff, we would place them in pretty high positions on the data or epi[demiology] side because they were just high performing.”

– Interviewee from an STLT public health agency

Although the program was successful overall, several interviewees described challenges related to the differences in salaries between STLT and CDC Foundation COVID-19 Corps staff as well as local public health agencies’ access to support from these staff. The CDC Foundation sometimes had difficulty recruiting specialized roles that STLT public health agencies needed, such as epidemiologists. With funding from CDC, the Foundation overcame this challenge by providing competitive pay and benefits to recruit top talent. However, this often meant exceeding compensation offered at STLT public health agencies for similar roles, leading to tensions between staff. One interviewee noted that some STLT health public agencies were able to address this issue by raising salaries for their regular employees. Others had difficulty hiring CDC Foundation COVID-19 Corps staff on a permanent basis because they could not offer salaries as competitive as the CDC Foundation. Another challenge was supporting small and medium-sized local health departments. The CDC Foundation primarily placed staff in states, territories, tribes, and big city local public health agencies, but smaller local public health agencies were not able to benefit from the CDC Foundation placements. This was particularly true in decentralized states in which state agencies operate separately from local agencies. As evidence of this challenge, nearly all of the interviewees from local public health agencies noted that they did not receive support from the CDC Foundation COVID-19 Corps.

Other foundations operated programs similar to the CDC Foundation’s COVID-19 Corps. Although the CDC Foundation’s staffing program was the largest and most frequently discussed program by interviewees, one interviewee from an STLT public health agency leveraged similar support from the Bill and Melinda Gates Foundation and found it helpful.

### III.1.B Staff placements through fellowship programs

Successes: Fellows filled key roles at no cost to STLT public health agencies.

Challenges: STLT public health agencies often had difficulty retaining fellows in permanent positions.

Fellowship programs helped to fill key roles at STLT public health agencies during the COVID-19 pandemic (at no cost to the agencies), but retaining fellows in permanent positions was a challenge. A few STLT public health agencies described leveraging staff from the federally funded pipeline and fellowship programs that place recent graduates in STLT public health agencies (see the call-out box). STLT agencies valued the support from the fellows and noted that they filled critical roles in the COVID-19 pandemic response. For example, one agency said Public Health Associate Program fellows “did everything the communicable disease staff did, and more.” Another interviewee described filling a key epidemiologist role with a Council of State and Territorial Epidemiologists fellow. Interviewees generally shared positive perceptions of these programs but described challenges retaining fellows as full-time staff. An interviewee noted that, nationally, only eight percent of Epidemic Intelligence Service graduates go on to work at STLT agencies.

Pipeline and Fellowship Programs used by STLT Public Health Agencies

CDC’s Public Health Associate Program (PHAP): Two-year training program that places recent graduates of bachelors and master’s programs related to public health in STLT public health agencies to support emergency preparedness and response, evaluation, program planning, and other activities. A total of 295 fellows participated in the 2019–2021 and 2020–2022 PHAP cohorts (CDC 2023c).

CDC’s Epidemic Intelligence Service (EIS): Two-year training program that places recent medical, veterinary, or nursing school graduates or graduates of doctoral programs at CDC or in STLT public health agencies to investigate and respond to disease outbreaks and other emergent public health threats. In 2020, 60 EIS fellows participated in the program (22 in STLT agencies), and 70 fellows participated in 2021 (22 in STLT agencies) (CDC 2023d).

Council of State and Territorial Epidemiologists (CSTE) Applied Epidemiology Fellowship: Two-year training program funded through CDC and HRSA that places recent graduates of master’s or doctoral programs in epidemiology in STLT public health agencies. Data on the number of Applied Epidemiology fellows during the COVID-19 pandemic were not available.

### III.1.C Deployment of CDC employees to STLT public health agencies

Successes: CDC staff filled key roles in STLT public health agencies in critical areas such as epidemiology and provided valuable expertise.

Challenges: Some STLT public health agencies requested more deployed staff than CDC could provide.

The CDC deployed full-time CDC employees to support STLT public health agencies in areas such as epidemiological investigations and data. In the first six months of the pandemic, CDC deployed more than 700 of its employees to provide in-person assistance to 55 STLT public health agencies responding to the COVID-19 pandemic (Dirlikov et al. 2020). The most common areas that that CDC employees supported were epidemiologic investigations, infection prevention and control in health care settings, health communications, community mitigation, and occupational safety and health. Some of the programs the CDC used to deploy staff to STLT public health agencies included the following:

- Preparedness Field Assignees Program. The Preparedness Field Assignees program places CDC-hired staff in STLT public health agencies for two-year assignments to support public health preparedness planning and response efforts (CDC 2023e). Currently, there are 25 Preparedness Field Assignees in the field, and, in 2023, the program will recruit an additional 10 new assignees (CDC n.d.).
- Career Epidemiology Field Officers (CEFO) Program. CEFOs are epidemiologists with experience in surveillance, epidemiology, preparedness, research, training, and policy development (CDC 2023g). CDC recruits, hires, and places the CEFOs in jurisdictions that receive funding through the CDC’s Public Health Emergency Preparedness (PHEP) cooperative agreement. An interviewee shared that, as of spring 2023, there were 50 CEFOs in 47 jurisdictions.

Staff deployed from CDC provided valuable support to state and territorial public health agencies, but agencies could have benefitted from more support. Interviewees noted that a key benefit of Preparedness Field Assignees, CEFOs, and other CDC staff deployments is that it is typically easier for CDC to hire these staff and place them in STLT public health agencies than for STLT public health agencies to hire them directly. This is because the higher salaries offered by CDC and the wider network of qualified candidates available to CDC. One interviewee also cited program limitations on the number of staff that the CDC can hire on behalf of jurisdictions. Some jurisdictions requested more deployed staff than CDC could provide through these programs. In addition, jurisdictions typically apply for a CEFO using funding from the CDC’s PHEP cooperative agreement to fund the position. As a result, public health agencies with the fewest resources typically did not have a CEFO placed in their agency because they used their PHEP funding to maintain basic public health capabilities. The interviewee shared that CDC has since expanded the CEFO program to guarantee a CEFO to every state, territorial, and large local jurisdiction directly funded by the PHEP cooperative agreement.

### III.1.D Deployment of personnel to public health agencies from other federally funded programs

STLT public health agencies commonly reported using personnel deployed from federally funded programs such as the National Guard, MRC, and Public Health AmeriCorps to surge their governmental public health workforce. Less commonly, STLT public health agencies also reported receiving support from the National Disaster Medical System and Federal Emergency Management Agency. While STLT public health agencies did not report using the U.S. Public Health Service (USPHS) Commissioned Corps, the USPHS Commissioned Corps’ medical, health and engineering professionals fight disease, conduct research, and care for patients in underserved communities across the nation and were deployed in support of COVID-19 response-and-recovery efforts during the pandemic (USPHS, n.d.). Here, we describe how STLT public health agencies leveraged a few of these programs to surge their workforce during the COVID-19 pandemic.

#### National Guard

Successes: National Guard was particularly helpful for filling logistical roles (for example, setting up tents at vaccination and testing sites).

Challenges: Many members did not have public health experience and struggled with some public health–related activities. Some STLT public health agencies felt uncomfortable placing uniformed National Guard members in certain communities. National Guard members were deployed for an undefined length of time, making it hard for STLT public health agencies to plan and strategize.

State and territorial public health agencies valued support from the National Guard to set up vaccination and testing sites, transport specimens, and support other roles, as needed. The National Guard is a state-based military force that provides trained units to states, territories, and the District of Columbia. Several STLT public health agencies shared that, during the pandemic, National Guard personnel were particularly helpful for logistical roles, such as setting up tents at vaccination and testing sites, staffing traffic control, providing security, and transporting specimens to and from collection sites. At the height of the pandemic, an estimated 40,000 National Guard personnel were deployed to states and territories to support the COVID-19 pandemic response (FEMA, n.d.). One STLT public health agency shared that the National Guard personnel were flexible and used to playing different roles to support changing needs.

Challenges working with the National Guard included their lack of public health training, uniformed presence, and undefined timelines for providing support. A few STLT public health agency interviewees said that, because National Guard personnel did not have public health experience, they struggled with some public health–related activities, such as accurately collecting and entering COVID-19 and demographic data in immunization records, adhering to confidentiality protocols, and operating with cultural humility. In addition, a few STLT public health agencies did not want to have uniformed personnel at vaccination or testing events because of concerns that it could be disconcerting for refugee communities or community members who are undocumented. An STLT public health agency also shared that there was a lack of clarity around how long the National Guard could provide support, making it challenging to strategize the best way to leverage National Guard personnel.

#### Medical Reserve Corps (MRC)

Successes: MRC volunteers are typically local, so they don’t need to travel and are known and trusted by the community. Agencies can use existing systems to conduct background checks and train MRC volunteers.

Challenges: Systems for supporting MRC volunteers to cross state lines, including vetting processes, housing, and liability protections could be strengthened.

Volunteers organized through the MRC provided useful support, especially to small local public health agencies. The MRC is a national network of locally organized volunteers who seek to improve the health and safety of their communities, and it includes volunteers with various skills, including medical, public health, safety, logistics, and communication. The Administration for Strategic Preparedness and Response operates the MRC and provides funding to build and maintain its emergency response and health equity capabilities. Currently, the MRC has about 300,000 volunteers, which increased by about 140,000 during the pandemic, and 800 MRC units nationwide. During the pandemic, more than 500 MRC units in 48 states, the District of Columbia, Puerto Rico, American Samoa, and the Northern Mariana Islands contributed to contact tracing and call center efforts (Administration for Strategic Preparedness and Response n.d.). The MRC has 10 regional liaisons who provide technical assistance to states on how to recruit, train, and deploy MRC volunteers. States also have state coordinators who collaborate with regional liaisons, local unit leaders, and state-level partners. A few interviewees from STLT public health agencies said that local MRC volunteers were particularly helpful because they did not have to travel and were known and trusted by community members. Another noted that it was easy to leverage MRC volunteers because they could leverage MRC systems to conduct background checks and train MRC volunteers rapidly.

Deploying MRC volunteers across state lines was sometimes challenging to manage and volunteer availability was inconsistent. One interviewee said that systems for supporting public health volunteers to cross state lines, including systems for vetting and tracking volunteers of for providing housing and reimbursements for travel, could be strengthened. Although the Emergency Management Assistance Compact (EMAC) supports volunteers to cross state lines in emergencies (for example, by recognizing medical licenses from volunteers’ home states in the state they are deployed), this interviewee noted that having a public health–specific EMAC might be more effective. Another interviewee described that strengthened tort and claims liability protections for medical volunteers serving across state lines could also be helpful. Additionally, a STLT public health agency said that relying on MRC volunteers was challenging at times because MRC volunteer availability was inconsistent.

“The challenging part was consistency: knowing we'd have consistent people that were trained and able to do the work.”

– STLT public health agency interviewee

#### Public Health AmeriCorps

Successes: Public Health AmeriCorps is a promising approach to support STLT public health agencies’ efforts to advance health equity and encourage young people to pursue careers or degrees in public health. It aims to place more than 4,000 members in 100 state and local organizations (including some public health agencies) in its first year in operation.

Challenges: Public Health AmeriCorps was implemented in 2021, so it was not available to support the STLT public health workforce surge at the outset of the COVID-19 pandemic.

Public Health AmeriCorps was introduced after the height of the COVID-19 pandemic, but interviewees noted its promise in encouraging younger people to pursue public health careers and its ability to support future pandemics. Public Health AmeriCorps is a new program established in 2021 through a CDC grant to support public health needs in state and local public health settings and advance more equitable health outcomes (AmeriCorps 2021). Health departments apply for competitive funding and can use the funds to hire and train people to work in the health department in roles related to health education and training; community outreach and engagement; system navigation, referrals, and linkage to care; and research, data collection, analysis, and assessments (CDC 2023g). In its first year of funding, the program provided nearly $70 million to 82 state and local organizations (CDC 2023g). In 2023, more than 100 grantees (including some state and local public health agencies) received Public Health AmeriCorps funding, totaling more than $90 million, with the goal of recruiting around 4,000 AmeriCorps members (AmeriCorps n.d.). Although none of the STLT public health agency interviewees reported using Public Health AmeriCorps to surge the workforce during the pandemic, other interviewees who work closely with STLT public health agencies shared positive feedback on the program, noting that the program encourages young people to pursue public health careers or degrees.

### III.1.E Partnerships to surge staffing or deliver public health interventions

Partnerships played a critical role in expanding staff capacity and building trusted relationships with communities to support the COVID-19 pandemic response. STLT public health agencies partnered with universities, community-based organizations (CBOs), public health institutes, hospitals and health systems, and other organizations to surge the public health workforce and deliver public health interventions.

#### Partnerships with universities

Successes: Student volunteers filled multiple roles and brought new energy to the workforce.

Challenges: Regulations limited the use of students in some settings (for example, nursing students were not authorized to administer vaccines). There was frequent turnover among student volunteers because of school schedules.

Many STLT public health agencies partnered or contracted with universities to surge the workforce. Most commonly, interviewees reported using student volunteers to support contact tracing, staff vaccine sites, and analyze data. A few STLT public health agency interviewees contracted with universities to fill physician or laboratory roles or to oversee contact tracing. One STLT public health agency repurposed a memorandum of understanding with a university to shift the goals of the partnership away from research on other bacterial diseases in the community to focus on COVID-19 testing and response. The literature similarly describes approaches to using student volunteers and staff and highlights STLT public health agencies’ collaboration with university partners to develop contact tracing training resources (Pogreba Brown et al. 2021; Toney et al. 2021; Woodard et al. 2022).

Several STLT public health agencies shared positive feedback about using university partnerships to bolster the public health workforce. For example, a few interviewees described how student volunteers brought new energy to the workforce. In another case, a public health agency partnered with a university that had longstanding relationships in a medically underserved community, making it easier to reach this community with information about COVID-19 vaccination.

Only a few interviewees noted challenges with university partnerships. One STLT agency said that regulations prevented nursing students from filling some roles such as administering vaccines, and another described frequent turnover and the need for constant training because of school schedules. In addition, one STLT agency felt that some university faculty and staff had difficulty transitioning from academia to a practice setting in local government.

#### Partnerships with CBOs

Successes: CBOs have trusted relationships in communities, which were valuable to STLT public health agencies during the COVID-19 pandemic. They are also effective at promoting health equity.

Challenges: The interviews identified no challenges.

Several STLT public health agencies partnered with CBOs to support contact tracing and vaccination in populations hardest hit by COVID-19 and advance health equity in the COVID-19 response. The literature highlights how STLT public health agencies partnered with CBOs to fill gaps in the public health workforce. For example, the city of Chicago and the Chicago Department of Public Health created grants for 31 CBOs to identify 500 community members for the health department to hire as contact tracers and supervisors (University of Illinois Chicago 2020). Similarly, the Oregon Health Authority released a grant program for CBOs to support state and local health departments’ efforts to educate communities about COVID-19, engage community health workers in contact tracing efforts, and provide wrap-around services to people in quarantine or isolation (Oregon Health Authority n.d.). CDC’s Partnering for Vaccine Equity Program provided funding to more than 200 CBOs (and other organizations) to support community-level efforts to improve COVID-19 and flu vaccinations. It is unknown, but possible that some of these CBOs may have formally partnered with their respective STLT public health agencies (CDC 2023h). Interviewees also valued CBOs as partners with trusted relationships in communities and noted that CBOs were particularly effective in reaching communities with information about COVID-19 vaccination. One interviewee described working with CBOs to address health equity in the COVID-19 response and planned to continue these partnerships to address equity issues and engage communities in future emergency response efforts.

#### Partnerships with hospitals and health systems

Successes: Hospital- and clinic-run COVID-19 testing and vaccination clinics were a critical resource in some communities.

Challenges: Some hospitals and health systems were too overburdened to be effective partners. Funding opportunities often went to hospitals to respond to the COVID-19 pandemic, without funding for public health agencies to partner and provide support.

The literature suggests the importance of partnerships with primary care providers to support health equity and address vaccine hesitancy in the COVID-19 pandemic response. For example, one study found that people in communities experiencing racism or harm from medical institutions often did not trust health care systems as a whole, but they did trust individual primary care providers (Lorvick et al. 2021). Initially, COVID-19 vaccination efforts focused on distribution through mass vaccination sites or hospitals, but there was later recognition of the critical role that primary care providers can play in supporting the vaccination workforce and building trust in communities (Aggarwal et al. 2023; CDC 2021). Although interviewees did not discuss partnerships with primary care providers in depth, one STLT public health agency mentioned partnering with Federally Qualified Health Centers to support vaccination and testing.

Although there is limited literature exploring hospital and public health partnerships, several STLT public health agency interviewees described their partnerships with hospitals to support COVID-19 testing and vaccination. Hospitals and health systems were often funded directly to address the COVID-19 pandemic and support testing and vaccination. However, there is limited literature exploring the extent to which these hospitals and health systems partnered with STLT public health agencies for these efforts. A few interviewees described partnerships with hospitals. In one case, hospitals staffed their own vaccination clinic with hospital staff and communicated regular updates to the health department. Hospital partnerships generally worked well, but one interviewee in a rural area mentioned that they had tried to establish a vaccination clinic with a hospital, but hospital staff were overburdened and did not have the capacity to support the clinic. A local public health agency interviewee also expressed frustration that funding often went directly to hospitals or large pharmacies to support COVID-19 vaccination, without recognition of the role that local public health agencies could play.

“What we had happen early and often in COVID is that from the federal level to the state level, there was this absolute need to put all hands on deck and to get everyone involved in fighting the pandemic. And there was much focus on that, including hospital systems and pharmacies‖with a total and insulting disregard for the trained public health workforce in the local health department‖we at the local public health level were training and teaching our federally qualified health centers, our local hospitals and our CVS and Walgreens pharmacies how to do what we knew how to do. They got the money to do it. We did not.”

– STLT public health agency interviewee

#### Partnerships with public health institutes

Successes: Public health institutes hired staff rapidly on behalf of STLT public health agencies, had trusted relationships with communities, and helped train the surged workforce.

Challenges: The interviews identified no challenges.

A few interviewees highlighted public health institutes as useful partners for surging the public health workforce and for training staff and managing the COVID-19 pandemic response. Public health institutes are non-profit organizations that belong to a National Network of Public Health Institutes focused on addressing public health issues in communities across the United States (National Network of Public Health Institutes 2023). As interviewees described, some public health institutes hired staff on behalf of state public health agencies, allowing those agencies to bypass slower government hiring processes. One interviewee noted that public health institutes also provided public health training for the surged workforce and had specialized knowledge of public health emergency management that allowed them to work alongside public health agencies to manage the COVID-19 pandemic response. One example of a successful public health institute partnership was the Institute for Public Health Innovation’s partnership with the Fairfax County Health Department in Virginia. As part of this effort, the Institute for Public Health Innovation hired 800 people for the health department, including investigators, contact tracers, community health workers, epidemiologists, data and environmental health specialists, and supervisors and managers (Kocsis et al. 2022).

### III.1.F Leveraging existing staff and hiring mechanisms

In addition to using new strategies to surge the governmental public health workforce, STLT public health agencies relied on existing staff and hiring mechanisms to respond to the COVID-19 pandemic. Most commonly, they reassigned staff from their typical roles or programs to focus on aspects of the COVID-19 pandemic response. STLT public health agencies also increased their reliance on third-party agencies to identify and recruit staff to place in their agency through contracts.

#### Reassignment

Successes: Reassignment provided immediate support for emerging needs such as contact tracing and case management.

Challenges: Reassignment contributed to burnout and staff departures, funding restrictions made it difficult to reassign some staff, and it left other programs or initiatives (not directly related to COVID-19) understaffed.

All STLT public health agencies that participated in interviews said they reassigned staff to meet the demands of the pandemic, but interviewees described numerous challenges. As described in Section II, these included the following:

- Some staff were unable to be reassigned because of restrictions in the way they were funded. A few STLT public health agency interviewees shared that certain funding sources did not allow them to reassign certain staff to support COVID-19 pandemic response efforts. For example, one STLT public health agency was unable to reassign staff supporting its Diabetes Prevention Program to pandemic response even though the Diabetes Prevention Program’s worksites were closed because of the pandemic.
- Core public health areas suffered. When STLT public health agencies reassigned staff to the COVID-19 pandemic response, their other public health programs, such as health promotion, became understaffed.
- Staff were reassigned to roles that did not align with their skill sets and training. Several STLT public health agencies noted that it was difficult to align staff member’s salaries and existing skills to new roles related to the COVID-19 pandemic. For example, one interviewee noted that a finance professional who had previously spent most of their time working in spreadsheets was reassigned to work in a position interacting with community members. Another interviewee describing having non-supervisory staff fill supervisory roles without changing their compensation. Interviewees said these scenarios contributed to increased job dissatisfaction among the STLT workforce.
- Reassignment contribued to staff burnout and challenges with retention. As noted in Section II, the reassignments often continued for months and contributed to burnout.

“Half the people from the chronic disease [program] were doing contact tracing. It had absolutely nothing to do with their work and they needed pretty significant support.”

– STLT public health agency interviewee

#### Contracting with staffing agencies

Successes: Contracting with staffing agencies is effective for quickly hiring large numbers of staff, such as contact tracers. It allowed STLT public health agencies to budget at the contract level rather than for individual staff.

Challenges: Establishing new contracts with staffing agencies can be complicated and expensive. Reliance on contractual staff contributes to turnover and issues with retention as employees seek permanent positions with better job security.

Nearly all STLT public health agencies that participated in interviews reported contracting with staffing agencies, and most said that they were effective at quickly hiring staff. Interviewees noted that staffing agencies were most often used to hire contact tracers, but they also helped fill other roles including nurses, epidemiologists, health educators, procurement staff, project managers, and IT staff. STLT public health agencies said that staffing agencies were able to quickly hire large numbers of staff, allowing them to focus on responding to the COVID-19 pandemic. Several key informants also shared that staffing agencies simplified the budgeting processes for STLT public health agencies because they only needed to budget for the contract instead of budgeting for specific staff. Another STLT public health agency shared that some contract staff brought valuable experience and were subsequently hired permanently.

Even though staffing agencies were, as one key informant noted, “integral to the response,” STLT public health agencies noted challenges with this hiring strategy. For example, a few interviewees shared that staffing agencies were less effective at hiring nurses and master’s-level employees such as epidemiologists and data specialists. Several interviewees highlighted that, initially, it can be difficult to establish contracts with staffing agencies because of administrative challenges, such as needing to establish multiple new contracts with staffing agencies, the high cost of contracting with staffing agencies, and lack of mechanisms to track staff across contracts. Two interviewees mentioned that the U.S. General Services Administration’s Multiple Award Schedule program was introduced to address some of these challenges with contracting, but they noted that it was not available until midway through the pandemic. Under the Multiple Award Schedule program, the General Services Administration establishes long-term contracts at pre-negotiated prices, and federal, state, and local agencies can quickly select from qualified vendors to purchase specific services and supports (U.S. General Services Administration 2022). Although none of the people we interviewed in the STLT public health agencies described using this mechanism to hire staff, it is possible that their agency did so without their knowledge.

Many interviewees highlighted the challenges associated with the temporary nature of most contract positions. One STLT public health agency noted that it was inefficient to invest in staff members’ training only to have to let them go at the end of their contract. Another agency shared that it can be challenging to scale operations down when staff members’ contracts end. Across interviewees, most noted that the basic structure of having so many public health roles filled by contracted staff contributes to turnover as workers seek permanent positions with greater job security.

## III.2 Surge supports that STLT public health agencies used during the COVID-19 pandemic

Next, we describe supports that STLT public health agencies relied on to fund surge strategies, train the surged workforce, and plan their COVID-19 pandemic response.

### III.2.A Federal funding

Successes: Federal funding is critically important for hiring staff to respond to the pandemic. Flexible funding opportunities such as CDC’s Infrastructure grant helped STLT public health agencies respond and hire staff as they saw fit.

Challenges: Most funding is provided over short (three to five year) intervals, making it hard to create and retain permanent, long-term positions. Lack of flexibility in some funding opportunities makes it challenging to use money to meet the agency’s most pressing needs. Small- and medium-sized STLT public health agencies do not have direct access to most federal funding opportunities.

STLT public health agencies used various sources of federal funding to support their COVID-19 pandemic response efforts. These sources (summarized in Appendix Exhibit C.2) most commonly included CDC’s Strengthening the U.S. Public Health Infrastructure, Workforce, and Data Systems Grant; the Coronavirus State and Local Fiscal Recovery Funds program authorized through the American Rescue Plan Act; CDC’s Public Health Preparedness cooperative agreement; and others described in Appendix C.2.

Several STLT public health agencies said federal funding was critical to their ability to quickly hire and build their public health workforce. Interviewees who work closely with STLT public health agencies noted that funding was most helpful for STLT public health agencies when it was flexible and distributed through larger funding opportunities (rather than across multiple small programs).

Although federal funding was critical to STLT public health agencies’ response efforts, agencies described challenges with the lack of flexibility and short-term nature of some funding opportunities. One STLT public health agency interviewee noted that the “urgency with which the money was provided” made it difficult to use funds in the allotted time. Several other interviewees questioned the long-term impact of funds and what their jurisdiction would do after the federal funding ended. STLT public health agencies also noted that categorical federal funding makes it difficult to pivot when new needs arise during an emergency. One STLT public health agency was unable to use staff hired under the emergency order to conduct other disease investigations even though they experienced a hepatitis outbreak among people experiencing homelessness in their community. Federal funds also have more laborious reporting requirements than other funding sources. For example, an STLT public health agency said that, when partnering with CBOs for immunization and testing activities, it chose to use “local dollars” instead of federal funds because many CBOs did not have the infrastructure to meet federal reporting requirements.

“It’s going to take a longstanding investment. A five-year investment isn’t going to cut it.”

– Interviewee from a public health organization

Several interviewees said that requiring federal funding to go through or get approved by the state before becoming available to local health departments decreased its effectiveness. This process limited the amount of time local health departments had to use the funds. It also reduced the funds available as states often “take a cut.” This process also gave states the authority to determine where and how the funds should be spent. Not all the STLT public health agencies we interviewed faced this issue, however, because CDC expanded the number of jurisdictions that it funded directly during the COVID-19 pandemic. One interviewee from a larger local public health agency described benefitting from this change, noting that it helped the agency respond quickly rather than wait for funds to funnel through the state.

Funders were aware of these challenges and are actively exploring solutions. For example, the CDC Moving Forward Summary Report (CDC 2022a) details strategies to reduce the burden on STLT public health agencies receiving federal funding and make it easier for them to use funds. Examples include simplifying grant management systems for applicants and awardees and ensuring that funding opportunities allow flexibilities to respond to emerging public health issues at the national or local level. One interviewee suggested that it might be more effective for federal funders to provide funding through partners, such as the CDC Foundation and other nonprofits, that might provide more flexibility than direct contracts through federal agencies.

### III.2.B Workforce planning tools

Successes: The Council of State and Territorial Epidemiologists’ epidemiology capacity assessment tool and the de Beaumont Foundation’s workforce calculator were helpful for some STLT public health agencies.

Challenges: Few workforce planning tools are available, and there is limited awareness of existing tools among STLT public health agency staff.

A few organizations developed resources to support STLT public health agencies in workforce planning. The de Beaumont Foundation and partners developed a Public Health Workforce Calculator that allows state and local public health agencies to gauge how many staff they need for the foundational public health service areas. The calculator, however, is only intended for use by health departments that have populations smaller than 500,000 people and health departments in states with a decentralized governance structure, where local health departments hire staff (PHNCI n.d.). Another interviewee shared that the Center for Public Health Systems provides technical assistance to STLT public health agencies on topics such as how to conduct community health needs assessments.

STLT public health agencies that participated in interviews generally did not know of or use workforce planning tools before or during the pandemic. One STLT public health agency interviewee said that it did not have a specific workforce strategy at the beginning of the pandemic and its goal was simply to hire as many staff as possible. Ultimately, the STLT public health agency conducted a workforce analysis using the Council of State and Territorial Epidemiologists’ epidemiology capacity assessment tool and developed an organization chart to define specific staff and teams’ span of control. Another STLT public health agency interviewee said that although it did not use any tools to estimate workforce needs during the pandemic, it is now conducting a foundational capabilities gap analysis to identify its capabilities and gaps. Two other STLT public health agency interviewees shared that they would appreciate workforce planning tools to use in the future.

### III.2.C Workforce/administrative planning data

Successes: A few STLT public health agencies used creative approaches to track their workforce.

Challenges: Existing workforce data are fragmented. The high volume of volunteers and temporary staff made it challenging for STLT public health agencies to track the workforce during COVID-19

Most STLT public health agency interviewees described challenges tracking their workforce. For example, one STLT public health agency interviewee shared that it had "bits and pieces" of data. One staff member was responsible for maintaining a roster of all employees in spreadsheets, but the high volume of temporary positions and volunteers made it challenging. Another agency shared that, during the pandemic, the agency "didn’t have time to think about [the] level of analysis" required for surge planning. One STLT public health agency said that although the agency does not have an accurate count of the number or FTEs of public health staff it employs across contracts, it is currently using CDC funding to clarify this information.

### III.2.D Other surge supports

Successes: Trainings for the surged workforce and peer-learning collaboratives (through federal agencies, public health organizations, and other groups) supported STLT public health agencies’ ability to surge the workforce.

Challenges: The interviews identified no challenges.

Federal agencies and public health organizations provided STLT public health agencies with peer-learning and technical assistance opportunities related to surging the workforce and trainings for new and surged staff. A few interviewees said that STLT public health agencies frequently engaged in forums for sharing lessons learned during the COVID-19 pandemic, including the Big City Health Coalition’s Workforce Commissioners Meeting, NACCHO convenings, and meetings with other STLT agencies organized by state public health associations. Some interviewees also described CDC’s public health workforce development trainings, including trainings designed for onboarding new staff to public health roles and focused on topics such as emergency preparedness and health equity. One interviewee mentioned that several STLT and federal public health agencies use trainings available through CDC TRAIN, an online platform in which federal agencies and grantees have shared more than 1,000 trainings on various public health topics (CDC Train n.d.), to onboard new staff. CDC also provided additional supports for surge staffing and emergency response to STLT public health agencies that received PHEP cooperative agreement funding, including health department liaison officers who served as connectors between STLT public health agencies and CDC, technical assistance on emergency response planning, and access to learning communities. Although health department liaison officers were previously only in place during emergency response, key informants believed they were effective, so CDC will be hiring health department liaison officers permanently.

The literature highlighted the Importance of policy supports to allow flexibility in hiring. For example, the Federal Public Readiness and Emergency Preparedness Act expanded the vaccination workforce by extending legal liability protections to pharmacists, dentists, midwives, and other health professionals. Nearly a dozen states enacted similar laws to expand providers’ scope of practice to administer COVID-19 vaccines (Davis and Evans 2021).

## III.3 Key takeaways from surging and supporting the public health workforce during the COVID-19 pandemic

Although each STLT public health agency used a different combination of strategies and supports to surge its public health workforce, interviews revealed some common successes. They also highlighted challenges and lessons learned related to hiring for specific roles, working with local public health agencies, and supporting equity in emergency response.

The most effective surge strategies allowed STLT public health agencies to bypass slow hiring processes in their agency to get immediate help from qualified staff and volunteers. These strategies (for example, using the CDC Foundation COVID-19 Corps, partnerships, and large volunteer programs such as the MRC) helped STLT public health agencies surge the workforce quickly, often at no cost, and filled gaps while STLT public health agencies were waiting for government approval of new positions or funding streams. STLT public health agencies also used fellowship and pipeline programs such as the Public Health Associate Program, the Epidemic Intelligence Service, and Public Health AmeriCorps on a smaller scale. If expanded, these programs have similar potential to surge the workforce during future emergencies and to build interest in public health careers among future generations.

It was harder to fill specialized public health and emergency management roles than roles that had fewer education and training requirements, but partnerships with universities, public health institutes, and the CDC Foundation offered effective solutions. Although programs such as the MRC and National Guard were generally effective at “getting boots on the ground” according to interviewees, these organizations did not always have the volunteers or staff STLT public health agencies needed to fill specialized positions such as epidemiologists, data analysts, or managers. Similarly, staffing agencies were generally viewed as helpful for recruiting contact tracers and staff to serve in temporary positions but were often less effective for recruiting and hiring people to fill roles that required higher levels of education and training. Universities and public health institutes, in contrast, were able to leverage deep expertise in public health, emergency management, nursing, or medicine to support STLT public health agencies during the COVID-19 pandemic. The CDC Foundation also recruited and hired for skilled positions in part by offering higher pay and benefits to attract talent.

Small and medium-sized local health departments tended to have fewer options for surging the workforce than states and large local public health agencies. Several interviewees from small and medium-sized local public health agencies voiced frustrations with a lack of support for local public health agencies, most notably regarding accessing federal funds and CDC Foundation COVID-19 Corps staff. Federal funds to support the COVID-19 pandemic response workforce were often channeled to states, territories, and large local public health agencies, and recipients were not always transparent about how the funds were subsequently allocated.

STLT public health agencies recognized a need for a workforce with an equity focus, cultural humility, and lived experience, and CBO partners often filled this need. Addressing the COVID-19 pandemic required outreach and engagement with communities hardest hit by the pandemic, often those that were historically oppressed by government entities and mistrustful toward the government. Strategies that employed uniformed government personnel, such as National Guard members, were not always culturally responsive and could present challenges for reaching these populations. STLT public health agencies found that working with CBOs helped to fill gaps in the workforce, as CBOs often had lived experience and longstanding relationships in communities and could serve as trusted messengers. They could also play critical roles as thought partners with STLT public health agencies to ensure the COVID-19 pandemic response was equity focused.

Interviewees felt that strategies to surge the public health workforce during public health emergencies are important but should not replace investments in foundational public health staff and competencies. Most interviewees noted that surge strategies and supports played a critical role in public health agencies’ ability to respond to the COVID-19 pandemic, but nearly all of these interviewees said that these strategies are not a replacement for long-term investments in STLT public health agencies. Tribal public health agencies also emphasized the historic underfunding of the Indian Health Service and lack of support for tribal public health in particular.

“Public health has been so woefully underfunded for such a long time and that became clear during COVID. And so, we had all this money thrown at us that we had to try to use and get out the door and hire new people on and a lot of that is coming to an end. My fear is that we're going to go back… to where we were pre-COVID…we won’t have the infrastructure that we need to be able to respond.”

– STLT public health agency interviewee