# II The Status of the Public Health Workforce

Here, we summarize national data sources that describe the STLT public health workforce (Section II.1), describe the size and characteristics of the STLT public health workforce before the COVID-19 pandemic (Section II.2), and highlight changes to the size and characteristics of the STLT public health workforce during the COVID-19 pandemic (Section II.3). We primarily present findings from the targeted literature scan and supplement these findings with qualitative data from the key informant interviews.

Key Estimates from the Literature

- 200,000 state and local public health workers were part of the workforce in 2019 (Kumar et al. 2022).
- 80,000 more FTEs were needed at state and local public health agencies to deliver foundational public health services leading up to the COVID-19 pandemic (de Beaumont Foundation 2021).
- 53,600 local health department employees were hired nationally from March 2020 to March 2021 (NACCHO 2022).
- 46 percent of the state and local public health workforce was estimated to have departed from 2017 to 2021 (Leider et al. 2023).

## II.1 Data sources describing the STLT public health workforce

Few national data sources provide information about the STLT public health workforce. Because there is no standardized system to classify staff by roles and expertise, and because of difficulties collecting and standardizing data across jurisdictions, information on the size and composition of the STLT public health workforce has historically been limited (Sumaya 2012). Most efforts to enumerate or describe the public health workforce use one of five sources: the Public Health Workforce Interest and Needs Survey (PH-WINS), National Association of County and City Health Officials (NACCHO) National Profile of Local Health Departments, the NACCHO Forces of Change Survey, Association of State and Territorial Health Officials (ASTHO) Profile of State and Territorial Public Health, or the New York State Association of County Health Officials Enumeration Survey. Exhibit II.1 has more information about these data sources.

Although helpful for providing insight into the STLT public health workforce, these data sources have noteworthy limitations, such as low response rates, infrequent data collection, and lack of tribal and territorial respondents. Low response rates are a challenge, especially for PH-WINS and the Forces of Change survey, both of which include respondents from small local health departments in the survey sample. The NACCHO and ASTHO Profiles have relatively higher response rates (61 percent and 98 percent, respectively, in 2019). Typically fielded every two to three years, the most recent NACCHO and ASTHO Profiles are from 2019 and cannot be used to assess changes in the public health workforce during the COVID-19 pandemic. Furthermore, these data sources have historically excluded tribal public health agencies and, to a lesser extent, territorial public health agencies, so they provide an incomplete picture of the STLT public health workforce.

Exhibit II.1 Data sources used to describe the STLT public health workforce

Data source (Data collection organization) | Data collection years | Description | Limitations
Public Health Workforce Interest and Needs Survey (PH-WINS) (de Beaumont Foundation and ASTHO) | 2014, 2017, 2021 | Collects data from a nationally representative sample of workers in state and local public health agencies (de Beaumont n.d.). | - Excludes tribal and territorial public health agencies; - Low response rate: the 2021 response rate was 35 percent (44,732 out of 137,446 state and local public health workers) (de Beaumont 2021b)
National Profiles of Local Health Departments (NACCHO) | 1989, 1992, 1996, 2005, 2008, 2010, 2016, 2019 | Questionnaire is distributed to local health departments nationwide (n = 2,459). The overall response rate in 2019 was 61 percent (1,496 local health departments out of 2,459 in the study population) (NACCHO 2020). | - No data collection during the pandemic; - Substantial item-level non-response because of the burden of responding to the survey and difficulty providing data on some topics (for example, finances)
Forces of Change Survey (NACCHO) | 2014, 2015, 2017, 2018, 2020 | Collects data from a random sample of local health departments (905 out of about 2,400 local health departments were included in the sample in 2020). Focuses on emerging topics in public health (NACCHO 2022). | - Low response rate (2020 response rate was 24 percent); - The sample excludes local health departments in Rhode Island and Florida
New York State Association of County Health Officials (NYSACHO) 2021 enumeration survey (NYSACHO) | 2021 | Distributed to all 58 local health departments in New York, of which 52 (89.7 percent) responded. Questions are designed to enable longitudinal comparison from 2019 to 2021 (Michaels et al. 2022). | - Lack of generalizability; only provides workforce data for local health departments in New York state; - Potential inconsistencies in reporting across local health departments because of unclear definitions of employee types
Profile of State and Territorial Public Health (ASTHO) | 2007, 2010, 2012, 2016, 2019 | Collects data from 50 states, the District of Columbia, and the eight U.S. territories and freely associated states. In 2019, 58 out of 59 states and territories responded. (ASTHO n.d.) | - No data collection during the pandemic

ASTHO = Association of State and Territorial Health Officials; NACCHO = National Association of County and City Health Officials; NYSACHO = New York State Association of County Health Officials.

## II.2 The public health workforce before the COVID-19 pandemic

The state and local public health workforce shrunk in the decade leading up to the COVID-19 pandemic. Using data from the ASTHO and NACCHO profile surveys, Leider et al. (2022) estimated that state and local public health workforce declined by more than 15 percent from 2008 to 2019, decreasing from 246,000 to 206,000 employees. Of the roughly 200,000 state and local public health employees in 2019, about one-quarter- were employed by state public health agencies, and the other three-quarters were employed by local public health agencies. Furthermore, the state and local public health workforce lacked diversity. Based on PH-WINS 2017, most of the public health workforce was non-Hispanic White (Leider et al. 2023).

One study estimated that the state and local public health workforce needed 80,000 more FTE positions to deliver foundational public health services, including basic emergency preparedness and response capabilities. To assess gaps in the workforce, the de Beaumont Foundation (2021) used survey data from the ASTHO and NACCHO Profiles and PH-WINS, as well as in-depth data from a sample of 170 local health departments and three state health departments collected in 2020 before the start of the COVID-19 public health emergency in the United States. The study estimated that state and local health departments needed to hire at least 80,000 more FTEs—an increase of almost 80 percent—to provide a minimum set of public health services to the nation. This included an 80 percent increase in the number of FTEs at state health departments (from 31,000 to 57,000 FTEs) and a 70 percent increase (from 72,500 to 126,500 FTEs) at local health departments. Among foundational areas, chronic disease and injury prevention were in the greatest need of additional FTEs. The literature described stagnant funding and inefficient hiring processes leaving STLT public health agencies struggling to attract talent to serve their communities (Alfonso et al. 2021; Gebbie et al. 2002; Sellers et al. 2019).

Most interviewees echoed these sentiments, noting that the public health workforce was understaffed and under-resourced before the COVID-19 pandemic. Interviewees said that the areas that lagged the most were nursing, roles that required higher levels of education or training (for example, epidemiology and disease investigative services), data management, and health equity. Interviewees who worked closely with STLT public health agencies highlighted that small local public health agencies tended to be the most understaffed and under-resourced.

## II.3 Changes to the public health workforce during the COVID-19 pandemic

Although we do not know the net changes to the size of the STLT public health workforce during the COVID-19 pandemic, rates of hiring and staff departure were high. As Exhibit II.1 shows, New York attempted to enumerate the public health workforce at local public health agencies during the pandemic. The study found that the net count of FTEs remained relatively stable from 2019 to 2021, increasing by only 1.7 percent (Michaels et al. 2022). These findings are limited to New York, however, and are not generalizable to local public health agencies in other states or regions or other types of public health agencies (for example, state, tribal, territorial). A study of local public health agencies nationwide using NACCHO’s 2020 Forces of Change Survey estimated that local health departments hired 53,600 employees from March 2020 to March 2021, with a mean of 1.8 new employees per 10,000 people in the jurisdiction (NACCHO 2022). The study did not, however, collect data on staff departures to estimate net change in the local public health agency public health workforce. STLT public health agencies that participated in interviews offered a more nuanced perspective. Although most interviewees noted that new hires exceeded departures in the first one-to-two years of the pandemic, a few said that staffdepartures spiked in 2022 and 2023 and guessed that the count of FTEs in 2023 is similar to pre-pandemic levels.

Staffing Changes at Public Health Agencies During the COVID-19 Pandemic

Interviewees from local public health agencies shared data and anecdotes about how their agencies’ workforce changed during COVID-19. For example:

- One interviewee described a 40 percent increase in FTEs from 120 FTEs pre-COVID to 170 FTEs at the height of the pandemic (in roughly 2020 and 2021).
- Another interviewee described a 25 percent increase in their agency’s workforce from 2,000 FTEs to 2,500 FTEs.
- A third interviewee described a 100 percent increase in their agency’s workforce from 600 FTEs to 1,200 FTEs during 2020.

Notably, each interviewee said that these levels dropped substantially in 2022 and 2023 as employees’ contracts ended and staff retired or quit, bringing the number of FTEs closer to pre-pandemic levels.

Most pandemic-related hiring occurred in 2020 and focused on contact tracers. Although the hiring surge continued through 2022, one study drawing on PH-WINS data suggests the proportion of newly hired staff at state and local public health agencies peaked from July 2020 to September 2020, with about 80 percent of pandemic-related hiring complete by March 2021 (McCullough and Robins 2023). Interviewees generally agreed that most hiring was done in the first year of the pandemic, noting that this early hiring was primarily for contact tracers and their supervisors. After eight or nine months, hiring efforts shifted to skilled staff such as epidemiologists, data experts, and communications specialists. A couple interviewees noted that additional hiring waves occurred during vaccine roll-out in late 2020 and 2021 and during the Omicron wave in late 2021 and early 2022.

The proportion of contractual and temporary staff at STLT public health agencies increased during the COVID-19 pandemic. One study using PH-WINS data from Big Cities Health Coalition members (that is, 35 of the largest local public health agencies serving at least 500,000 people) estimated that, from 2017 to 2021, temporary and contract workers increased their share of the public health workforce in big city public health agencies from 5 percent to 14 percent (Juliano et al. 2023). In the New York study, the count of full-time, part time, and seasonal FTEs declined from 2019 to 2021 (by 26 percent, 9 percent, and 45 percent, respectively), but the number of contractual FTEs increased from 13.7 in 2019 to 1,686 in 2021 (Michaels et al. 2022). Interviewees overwhelming reported hiring contractual and temporary staff to respond to the pandemic. All but one STLT public health agency interviewee noted that most of their new hires during the COVID-19 pandemic were contract staff, mainly because it was easier and quicker to hire contractual staff than to directly hire new employees.

The roles of public health workers shifted during the pandemic, with most employees being reassigned to roles supporting the pandemic response. Using PH-WINS data to assess reassignment at state and local public health agencies, one study estimated that nearly three-quarters of public health workers were reassigned to work on the pandemic response and that reassignment rates were higher at smaller agencies (for example, at local versus state public health agencies and at medium versus large local public health agencies) (Hare Bork et al. 2022). Similarly, on the NACCHO 2020 Forces of Change survey, 80.5 percent of local health departments reported that they reassigned existing staff from their regular duties to the agency’s COVID-19 pandemic response (NACCHO 2022). Relatedly, all STLT public health agencies that participated in interviews reported that their agency relied heavily on reassignment. Interviewees noted that they typically reassigned staff from areas such as crisis management, health promotion and education, and environmental health to work on contact tracing, case management, procurement, isolation and quarantine efforts, vaccination events, and COVID-19 data entry. Reassignment periods were originally envisioned as lasting a few weeks, but they often went on for months or even years, contributing to staff burnout and job dissatisfaction. An interviewee that works closely with STLT public health agencies reinforced the PH-WINS finding, sharing that the smallest local public health agencies had to reassign the most staff to meet the demands of the COVID-19 pandemic.

Meanwhile, staff departed the STLT public health workforce at alarming rates during the pandemic. Using PH-WINS data, Leider et al. (2023) estimated that half of the state and local workforce departed from 2017 to 2021, with young staff (age 35 and younger) and staff with short tenure (five years or fewer) most likely to have departed. Departures extend to more tenured employees as well: from March 2020 to February 2022, journalists from the New York Times identified more than 500 public health leaders who left their positions, resulting in a significant loss of executive leadership and experience (Baker and Ivory 2022). Several interviewees highlighted the rise in staff departures in 2022 and 2023, noting that many employees “stuck it out” through the worst of the pandemic but departed the workforce in alarming numbers as the public health emergency ended, either because of deferred retirements, burnout, or opportunities with higher pay and better benefits. It is also unclear how many staff newly hired during the COVID-19 pandemic will stay in their positions. In November 2022, the CDC Foundation estimated that 80 percent of public health professionals who were placed in state and local health departments through the foundation will leave, while only 20 percent (about 800 of 4,000) will continue to staff their jurisdictions on a longer-term basis (Weber 2022).

“COVID 19 just further exacerbated the huge cracks in the foundation of the infrastructure of public health.”

– STLT public health expert

Now that the public health emergency has ended, challenges with hiring and retention persist. In the literature and interviews, the most common barriers to hiring and retaining talent at STLT public health agencies include lack of sustained public health funding, burnout or high workload, low salaries and lack of advancement opportunities, slow or inflexible hiring mechanisms, and lack of diversity in the workforce (Leider et al. 2021; Bogaert et al. 2023; Yeager et al. 2023; Juliano et al. 2023). Although STLT public health agency interviewees were proud of their agencies’ efforts to surge the workforce, they also expressed concerns about hiring and retaining enough staff to support foundational public health areas, which includes the ongoing response to the COVID-19 pandemic and planning for future emergencies.