# I Overview

The governmental public health workforce in the United States performs a wide range of activities, including essential duties (known as foundational public health services), to improve the health and well-being of the communities it serves.^1^ During public health emergencies such as pandemic brought on by coronavirus disease 2019 (COVID-19), people rely on the public health workforce to be able to expand rapidly to respond to emerging threats while maintaining foundational public health services.

Despite noteworthy attempts to quantify the governmental public health workforce in the United States, there is no comprehensive data source to monitor the size and composition of the workforce. Enumeration attempts have been hindered by the complexity of the U.S. governmental public health infrastructure, which spans more than 2,800 local health departments, 51 health departments in each state plus the District of Columbia, eight territorial or freely associated state public health agencies, the entities that have public health authority for members of the 574 federally recognized American Indian/Alaska Native tribes, and hundreds of district and regional offices (Kumar et al. 2022; CDC 2023a). These state, tribal, local, and territorial (STLT) public health agencies vary in governance structure, size, population needs, and reporting capabilities, making it difficult to collect consistent data on number of employees and roles nationwide.

Study Definitions

STLT governmental public health workforce: Staff (including direct employees and contractual staff), volunteers, and other personnel who supported public health efforts in STLT public health agencies’ jurisdictions. This includes staff hired by STLT public health agencies, federal personnel deployed to jurisdictions, fellows and trainees, staff from partner organizations, and personnel placed in STLT public health agencies through organizations such as the CDC Foundation.

Surge strategies: Approaches that STLT public health agencies used to increase their workforce during COVID-19. Examples include CDC Foundation staff placements, partnering with other organizations, working with staffing agencies, and leveraging Medical Reserve Corp volunteers. We discuss these strategies in detail in Section III.2.

Surge supports: Funding, tools, and technical assistance designed to help STLT public health agencies address staffing challenges and implement surge strategies. We discuss these supports in detail in Section III.3.

Nationally representative data on the governmental public health workforce suggest that the workforce was significantly under-staffed to deliver core public health services for more than a decade leading up to the COVID-19 pandemic (Leider et al. 2022; Merrill et al. 2003; Sellers et al. 2019). For example, a study conducted by the de Beaumont Foundation (2021) estimated that another 80,000 full-time equivalent (FTE) positions were needed at state and local public health agencies to deliver foundational public health services before factoring in the COVID-19 pandemic.

The COVID-19 pandemic exacerbated the staffing challenges that the governmental public health workforce faced. As the demands on the public health workforce increased dramatically to control the spread of COVID-19, staff were reassigned from their normal roles to focus on pandemic response, further reducing the number of staff dedicated to core public health services.

There is a lack of visibility into the number and type of staff hired during the COVID-19 pandemic, and limited efforts to describe the range of strategies and supports that STLT public health agencies used to surge the public health workforce during that time. Due to staffing and time constraints, fewer STLT public health agencies had the capacity to respond to surveys or other efforts to quantify or describe changes to workforce during the pandemic. As a result, there is relatively limited information on the size of the governmental public health workforce during the pandemic, with most literature focusing on descriptions of burnout and intimidation or personal threats to safety. Additionally, although programs and organizations such as the CDC Foundation and Medical Reserve Corps (MRC) are increasingly sharing lessons learned from their efforts to support the pandemic workforce surge, (Medical Reserve Corps 2021; Buchdahl 2023) the existing literature does not synthesize, compare, or contrast these strategies. The same is true for supports intended to bolster the governmental public health workforce’s capability to respond to the pandemic, such as federal funding, training, and technical assistance to STLT public health agencies.

Meanwhile, the federal government is making substantial investments in the governmental public health workforce. Through the American Rescue Plan Act and the Centers for Disease Control and Prevention’s (CDC’s) grant, Strengthening U.S. Public Health Infrastructure, Workforce, and Data Systems (OE22–203), the federal government has invested about $8.5 billion (Congressional Research Services 2021; CDC 2023b). After years of underinvestment in public health, this represents a promising opportunity to strengthen the capacity of the public health workforce and prepare for future pandemics.

In response to the sparse information on the STLT public health workforce during the COVID-19 pandemic, the Office of the Assistant Secretary for Planning and Evaluation (ASPE), part of the U.S. Department of Health and Human Services, funded this study. The study explored the existing literature on the size and composition of the governmental public health workforce at STLT public health agencies before and during the COVID-19 pandemic as well as strategies and supports used by STLT public health agencies to surge the public health workforce during the pandemic. This study focuses on governmental public health, but there are also many organizations outside of STLT governments that addressed the COVID-19 pandemic and contribute to the public’s health; understanding the workforce at these organizations was beyond the scope of this study. Appendix A lists the full set of research questions. To address the research questions, the study team conducted an environmental scan; a targeted literature review; and 27 semistructured key informant interviews with state and local health officials, federal government officials, and other workforce experts involved directly or indirectly in surge staffing. Appendix B describes the study methods in detail.

This white paper presents findings on the following:

- The status of the public health workforce at STLT public health agencies before and during the COVID-19 pandemic (Section II)
- Strategies and supports that STLT public health agencies used to surge the STLT public health workforce during the COVID-19 pandemic (Section III)
- Lessons learned and suggestions for directing investments in the STLT public health workforce to prepare for future pandemics (Section IV)

1 Foundational public health services cover seven foundational capabilities (that is, cross-cutting skills needed to support basic public health programs) and five foundational areas (that is, topic-specific programs aimed at improving the health of communities). Foundational capabilities include emergency preparedness and response, assessment/surveillance, policy development and support, communications, community partnership development, organizational administrative competencies, and accountability/performance management. Foundational areas include communicable disease control, chronic disease and injury prevention, environmental public health, maternal and child health, and access to and linkage with clinical care. More information is available at https://phnci.org/transformation/fphs.