# Appendix C Summary Tables

Exhibit C.1 Summary of surge strategies and supports during the COVID-19 pandemic

Strategy | Successes | Challenges
The CDC Foundation’s COVID-19 Corps | - Program was newly and quickly implemented during the COVID-19 pandemic; - Quickly hired and placed highly qualified candidates at no cost to STLT public health agencies | - The CDC Foundation COVID-19 Corps staff were often paid higher salaries than STLT public health agency staff, creating tension; - Primarily supported states, territories, tribes, and big city local health jurisdictions; smaller local public health agencies did not always get to benefit from this resource
Staff placements through fellowship programs | - Fellows filled key roles at no cost to STLT public health agencies | - STLT public health agencies often had difficulty retaining fellows in permanent positions
Deployment of CDC employees to STLT public health agencies | - Filled key roles in STLT public health agencies; - CDC offered higher salaries than most STLTs could, leading to better success with recruitment | - Some jurisdictions have asked CDC to hire and deploy more staff than it is currently able to through these programs
Deployment of personnel to public health agencies from other federally funded programs | [underlined: Public Health AmeriCorps]; - Promising approach to support STLT public health agencies’ efforts to advance equitable health and encourage young people to pursue careers or degrees in public health; - Funding for the second year of the program will support more than 4,000 members; [underlined: MRC]; - Local MRC volunteers don’t need to travel and are known and trusted by the community; - The national MRC network has systems in place to conduct background checks and train MRC volunteers; [underlined: National Guard]; - Particularly helpful for logistical roles, such as setting up tents at vaccination and testing sites | [underlined: Public Health AmeriCorps]; - Implemented in 2021, so it was not available to support the STLT workforce surge at the outset of the COVID-19 pandemic; [underlined: Medical Reserve Corps]; - Volunteers might not always be licensed to practice in the state they are deployed; [underlined: National Guard]; - Deployed for undefined length of time; - Mostly consists of younger staff who did not have public health experience and had difficulties performing public health–related activities; - Uniformed personnel could be concerning for refugee communities or community members who are undocumented
Partnerships to surge staffing or deliver public health interventions | [underlined: Partnerships with universities]; - Student volunteers filled multiple roles and brought new energy to the workforce; [underlined: Partnerships with CBOs]; - CBOs have trusted relationships in communities; - Effective in reaching underserved communities and promoting health equity; [underlined: Partnerships with hospitals and health systems]; - Hospital-run COVID-19 testing and vaccination clinics were a critical resource in some communities; [underlined: Partnerships with public health institutes]; - Hired staff rapidly on behalf of STLT public health agencies; - Had trusted relationships with communities; - Helped train the surged workforce | [underlined: Partnerships with universities]; - Regulations limited use of students in some settings (for example, nursing students were not authorized to administer vaccines); - Frequent turnover among student volunteers because of school schedules; [underlined: Partnerships with CBOs]; - No challenges identified in interviews; [underlined: Partnerships with hospitals and health systems]; - Some hospitals were too overburdened to be effective partners; - Health systems received funding to respond to the COVID-19 pandemic, without clearly establishing opportunities for public health agencies to partner and provide support; [underlined: Partnerships with public health institutes]; - Less effective when public health institute staff were not integrated in supervisory and management roles in the STLT public health agency
Leveraging existing staff and hiring mechanisms | [underlined: Reassignment]; - Provided immediate support for emerging needs such as contact tracing, case management, and so on; [underlined: Contracting with staffing agencies]; - Effective for quickly hiring large numbers of staff, such as contact tracers; - Allows STLT public health agencies to budget at the contract level rather than for individuals | [underlined: Reassignment]; - Contributed to burnout and staff departures; - Funding restrictions can make it difficult to reassign some staff; - Can leave other programs or initiatives (not directly related to the COVID-19 pandemic) understaffed; - Reassigning staff to roles that use their skill set is difficult; [underlined: Contracting with staffing agencies]; - Establishing contracts with third-party agencies can be challenging and expensive; - It is inefficient hiring and training contract staff who leave after their contract term ends
Federal funding | - Critically important for hiring staff to respond to the pandemic; - Flexible funding opportunities (for example, CDC’s Infrastructure grant) helped STLT agencies respond and hire staff as they saw fit | - Funding is provided in short intervals, making it hard to create and retain permanent long-term positions; - Lack of flexibility in some funding opportunities makes it challenging to use money to meet the agency’s most pressing needs; - Small and medium-sized STLT public health agencies do not have direct access to most federal funding opportunities
Workforce planning tools | - The CSTE’s epidemiology capacity assessment tool and the de Beaumont Foundation’s workforce calculator were helpful for some STLT public health agencies | - STLT public health agencies noted a lack of useful workforce planning tools
Workforce/administrative planning data | - A few STLT public health agencies used creative approaches to track their workforce | - Existing workforce data are fragmented; - The high volume of volunteers and temporary staff made it challenging to track the workforce
Other supports | - Trainings for the surged workforce and peer-learning collaboratives (through federal agencies, public health organizations, and other groups) supported STLT public health agencies’ ability to surge the workforce | - The interviews identified no challenges

CBO = community-based organization; CDC = Centers for Disease Control and Prevention; MRC = Medical Reserve Corps; STLT = state, tribal, local, and territorial.

Exhibit C.2 Federal funding sources that STLT public health agencies commonly used during COVID-19

Federal funding source | Description | Funding recipients
CDC’s Strengthening U.S. Public Health Infrastructure, Workforce, and Data Systems Grant^a^ | - Expected to award $4.5 billion over five years to help U.S. health departments promote and protect health in their communities; - The grant funding became available on June 23, 2022 | 107 jurisdictions (50 states, eight U.S. territories, and 48 large local public health agencies); three national partners that support the work
CDC’s Public Health Emergency Preparedness cooperative agreement^b^ | - Provided $650 million in funding for emergency response from July 1, 2023, to June 30, 2024; - Funds about 3,000 FTEs hired through STLT public health agencies | 62 jurisdictions (50 states, four cities, and eight U.S. territories and freely associated states)
Coronavirus State and Local Fiscal Recovery Funds program (American Rescue Plan Act)^c, d^ | - Authorized by the American Rescue Plan Act, provides $350 billion to STLT governments to support their response to and recovery from COVID-19 from March 2021 through December 2024 | More than 30,000 recipient governments, including states, tribal governments, territories, and local governments
CDC’s Epidemiology and Laboratory Capacity for Prevention and Control of Emerging Infectious Diseases Cooperative Agreement^e^ | - Provides annual funding to prevent and respond to infectious disease outbreaks, bolster laboratory and epidemiologic capacity, maintain and enhance health information systems, and foster cross-cutting solutions to address public health needs; - Awarded about $350 million for fiscal year 2022 | 64 state, large local, and U.S. territory and affiliate health departments.
American Rescue Plan Act funding for MRC,^f^ administered through the MRC STRONG grant | - Provided $100 million to the MRC, of which MRC awarded $50 million to states and jurisdictions through the MRC STRONG grant; - Grant funding first became available in March 2023 | 33 states and jurisdictions
The Operational Readiness Awards ^g^ | - The National Association of County and City Health Officials distributed 202 awards in 2020, totaling $1.1 million; 174 awards in 2021, totaling $1.56 million; and 120 awards in 2022, totaling $1.025 million; - Intended to build the operational readiness capabilities of MRC volunteers and units to meet the emergency preparedness and response needs of their local, regional, or statewide stakeholders | 202 MRC units in 2020; 174 MRC units in 2021; 120 MRC units in 2022

Notes: Large localities are cities serving a population of 400,000 or more and counties serving a population of 2,000,000 or more based on the 2020 U.S. Census.

CDC = Centers for Disease Control and Prevention; FTE = full-time equivalent; MRC = Medical Reserve Corps; STLT = state, tribal, local, and territorial; STRONG = State, Territory and Tribal Nations, Representative Organizations for Next Generation.

a CDC 2023i.

b CDC. 2023j.

c U.S. Department of Treasury n.d.

d U.S. Department of Treasury 2022.

e CDC. 2022b.

f Administration for Strategic Preparedness and Response 2023.

g NACCHO 2021.