# Appendix B Methods

The study included a targeted literature review and 27 semistructured interviews. Here, we describe our study methods.

## Literature review

We conducted a targeted literature review in March and April 2023. The primary goal of the literature review was to address the research questions related to the status of the public health workforce before and during the COVID-19 pandemic (RQs 1 and 2), but we also reviewed literature about surge strategies to inform key informant interview data collection (described below).

We identified peer-reviewed and gray literature for the environmental scan by searching PubMed, public health agencies’ websites, and Google. We used the following approaches to identify relevant literature, which we organized in EndNote:

1. Searched PubMed for peer-reviewed journal articles: We conducted a PubMed search using the following search terms:
  - ((public health[ti] OR health depart*[ti]) OR “public health”[ti:~2] OR “health department”[ti:~3]) AND (job[ti] OR jobs[ti] OR worker*[ti] OR workforce[ti] OR working[ti] OR work[ti] OR employ*[ti] OR staff[ti] OR staffing[ti] OR contract*[ti] OR career*[ti] OR professional*[ti] OR graduat*[ti] OR personnel[ti] OR labor*[ti]))
  We identified these search terms by reviewing a subset of relevant literature. We restricted the PubMed search to articles published from 2020 to 2023 to focus on findings during the COVID-19 pandemic. We further reviewed abstracts returned in this search and excluded articles that met the following criteria:
  – Focused on countries other than the United States
  – Did not describe workforce issues (for example, articles with “employees” in the title that discussed a cohort of employees’ experiences with vaccination)
  – Did not focus on building the public health workforce (for example, we included articles that focused on internships, graduate, and pipeline programs, workforce forecasting, and surging the workforce, but we did not include articles focused solely on trainings provided to public health professionals)
  – Focused on burnout or the mental health of the public health workforce during the COVID-19 pandemic in the absence of quantitative data on rates of staff departure (though we included in our review articles that discussed reasons for departures in conjunction with quantitative data)
2. Searched resource pages on websites of key public health agencies and organizations: We conducted focused searches on the websites of key public health agencies to identify relevant publications and data quantifying the public health workforce before and during the COVID-19 pandemic. These included the following:
  – CDC’s page
  – The Association for State and Territorial Health Officials’ homepage, using a search for “workforce”
  – The National Association of City and County Health Officials’ Workforce Development and Training page
  – Tribal epidemiology center webpages for information on the tribal public health workforce
  – The Health Resources and Services Administration’s page
  – The Public Health National Center for Innovations page
  – The Public Health Foundation page, including information on the Council on Linkages between Public Health and Academia
  – The Big Cities Health Coalition page, including information on emergency preparedness and response
  – The Administration for Strategic Preparedness and Response homepage, using a search for “workforce”
  – The National Network of Public Health Institutes, including the organization’s resource directory
  – The de Beaumont Foundation page, including the resources section
  – The CDC Foundation page, using a search for “workforce”
  – The Association of Schools and Programs of Public Health page, with a search for “workforce”
3. Conducted additional Google searches: We conducted broad searches in Google for “US public health workforce” and “US public health workforce 2020 – 2023” and skimmed for relevant gray literature that was not uncovered in previous searches. Although we used the inclusion and exclusion criteria above to inform which articles we selected, we did not systematically apply these criteria to each article returned in the search.

Initial PubMed searches for peer-reviewed literature returned 768 articles. After applying exclusion criteria, we identified 52 articles to include in the full-text review. Our searches for gray literature on Google and relevant public health agency websites yielded 61 publications.

In total, we closely reviewed 113 pieces of peer-reviewed and gray literature. We extracted information from the literature related to the public health workforce during the peak of the COVID-19 pandemic as well as the strategies or mechanisms used to surge the public health workforce during the pandemic. We also identified gaps in the information that we used to develop interview guides for the key informant interviews. Key findings from the literature review are available in Section II, although we cite relevant sources throughout the white paper.

## Key informant interviews

To address the research questions about surge strategies (RQ3), workforce planning tools (RQ4), and recommendations for future pandemics (RQ5), we conducted 27 semistructured interviews with key informants (KIs) from May 15, 2023, to June 30, 2023. We received expedited approval from HML Institutional Review Board on May 8, 2023.

To select key informants for the interviews, Mathematica collaborated with ASPE, who also reached out to stakeholder organizations. We identified 27 potential KIs and 15 alternates. We categorized KIs into three groups: (1) STLT public health officials (9 interviews), (2) leaders from federal agencies and organizations that were directly involved in surge staffing (10 interviews), and (3) public health workforce experts from organizations that were indirectly involved in surge staffing (8 interviews). The 9 interviews with STLT public health officials included a small but varied sample. The KIs represented public health agencies from 8 of the 10 Health and Human Services geographic regions and included all four levels of public health agency (state, tribal, local, and territorial). The sub-set of KIs from local public health agencies included officials representing small jurisdictions (serving fewer than 50,000 people), medium-sized jurisdictions (serving 50,000 to 500,000 people) and large jurisdiction (serving more than 500,000 people), as well as a mix of urban and rural jurisdictions. Across the 27 interviews, all KIs were in leadership positions. Tenure ranged from less than one year to more than 10 years.

Beginning in mid-May 2023, Mathematica reached out to potential KIs by email and phone using approved templates and scripts. For each potential KI, we attempted three emails and up to two phone calls. Potential KIs from three organizations did not respond to our outreach efforts so we replaced them with alternates in the same categories. We used warm hand-offs from colleagues at ASPE and internal Mathematica colleagues to facilitate completion of the interviews. In addition, we offered flexible scheduling and offered to reduce the length of interviews from 60 to 30 minutes for potential KIs that voiced concerns about time constraints.

Four experienced Mathematica team members interviewed the KIs by phone using three unique interview guides tailored to the three categories of KIs. Interviewers used semistructured interviewing techniques to collect rich details from KIs, adapting the order of topics and questions, as needed. All interviewers completed a training on the interview guides and a refresher training on semistructured interviewing best practices before beginning the interviews.

Interviewers requested consent from KIs to audio record the interviews and then transcribed them. The team of four coded the transcripts in NVivo using a codebook that aligns with the research questions and surge strategies and supports (Exhibit B.1). The team summarized coded data segments in a matrix with one row per KI and one column per code. We reviewed the matrix vertically (to assess findings from individual KIs) and horizontally (to assess themes across KIs) to identify themes and key takeaways. Unless otherwise noted, the interview themes included in the white paper represent the viewpoint of at least three key informants. We used descriptors such as “a few” (three to five key informants), “most” (more than half of key informants), and “nearly all” (more than 90 percent of key informants) to describe the number of key informants that reported a given theme.

Exhibit B.1 Qualitative codebook for the KI interviews

Code | Description
1.1 Baseline status and gaps in workforce roles or competencies before the COVID-19 pandemic | Provides on overall description of the public health workforce before the COVID-19 pandemic and/or notes a specific workforce need or gap before the COVID-19 pandemic.
2.1 COVID-19 pandemic staff gained or departed | Provides an anecdotal or numerical description of the number and types of staff or volunteers that were hired or that departed during the COVID-19 pandemic, and the timing of when staff were hired or departed.
2.2 COVID-19 pandemic gaps in workforce roles or competencies | Notes a specific workforce need or gap during the COVID-19 pandemic. Describes how workforce needs changed with COVID-19 or notes that the needs pre-pandemic were exacerbated during the COVID-19 pandemic.
2.3 Staff reassignment | Describes the number or types of staff that were re-assigned during the COVID pandemic and/or describes the implications of staff re-assignment.
2.4 Staff retention | Describes challenges or successes with retaining staff during the COVID-19 pandemic.
3.01 Third-party or staffing agency | Describes using a third party, such as a temp agency or staffing agency, to surge staff for temporary or contract positions. Excludes contract staff paid/recruited through CDC Foundation (code to CDC-F) or public health institutes (code to partnerships with other orgs).
3.02 Placement of fellows | Describes a strategy that places fellows directly in public health agencies, at no cost to the health department (for example, PHAP, EIS, CSTE fellows).
3.03 CDC Foundation | Describes the CDC Foundation’s efforts to support surge staffing.
3.04 Medical Reserve Corps | Describes use of the Medical Reserve Corps to support the public health workforce.
3.05 Public Health AmeriCorps | Describes use of Public Health AmeriCorps to surge the public health workforce.
3.06 Partnerships with CBOs | Describes a strategy related to partnerships with CBO to surge the workforce.
3.07 Partnerships with universities | Describes a strategy related to partnerships with a university (including with faculty and/or students) to surge the workforce.
3.08 Partnerships with other organizations | Describes a strategy related to partnerships with a private sector or health care organization partner, public health institutes, or other partners.
3.09 Federal funding | Describes how federal funding was used and/or allocated to support surging the workforce.
3.10 National Guard | Describes a strategy related to working with the National Guard to surge the workforce.
3.11 Other strategy | Describes a strategy that does not fall into the above buckets.
3.12 General perceptions | Does not mention a specific workforce surge strategy but provides general thoughts on strategies overall, such as “each state used different strategies” or “no strategies were effective for hiring data staff.”
3.13 Challenge with strategy | Describes a challenge developing or implementing a particular strategy. Describes why a particular strategy was ineffective for the participant’s organization. Double-code with a strategy code (3.01 – 3.12).
3.14 Success with strategy | Describes factors that helped facilitate the success of a particular strategy. Describes why a strategy was effective for the participant’s organization. Double-code with a strategy code (3.01 – 3.12)
4.1 Surge forecasting or planning models | Describes surge forecasting or planning models, gaps in available models, types of models that would have been useful to support surge planning, or any model currently in development to support planning for future pandemics.
4.2 Data for surge planning | Describes types of data to support surge planning.
5.1 Federal recommendations | Provides specific recommendations or lessons learned for federal agencies to better support the public health workforce surge in future pandemics. This could include supports, investments, changes to policy, or other suggestions/recommendations.
5.2 STLT recommendations | Provides specific recommendations for state, tribal, local, and territorial public health agencies to implement to support the public health workforce surge in future pandemics.
5.3 Other organization recommendations | Provides specific recommendations or lessons learned for other organizations to better support the public health workforce surge in future pandemics.
5.4 General or unspecified lessons learned | A respondent shares general recommendations or lessons learned for the field of public health to prepare for future pandemics.
5.5 Involvement in future workforce surge | Describes which agencies or partners should be involved in the workforce surge in future pandemics and how.

CBO = community-based organization; CSTE = Council of State and Territorial Epidemiologists; EIS = Epidemic Intelligence Service; PHAP = Public Health Associate Program