# Appendix A Research Questions

This study addressed the following research questions:

1. What was the baseline status (numbers, roles, competencies) of the STLT public health workforce before the pandemic? What were the gaps?
2. What was the status of the public health workforce during the peak of the pandemic? How many new staff were engaged, and of what type? To what extent were staff reassigned from their existing roles to roles within the COVID-19 response (either part or full-time)?
3. What strategies or mechanisms were used by STLT public heatlh agencies to surge the public health workforce?
  a. Which were most effective and efficient?
  b. What barriers to hiring did these mechanisms help overcome, and how?
  c. Which strategies were most suitable for specific types of staff?
  d. Why were certain mechanisms more effective in certain jurisdictions?
  e. Were there any pipeline strategies already in place that were able to deliver new staff?
    Were there any pipeline strategies newly put into place during the COVID-19 response that were able to deliver new staff?
4. Were any forecasting or workforce models or surge planning handbooks used and how were they helpful, if at all? What data were used to inform hiring decisions? How did the lack of robust data hinder effective hiring?
5. What are the lessons learned from staffing during the COVID-19 pandemic that will inform (1) federal and state or local strategies for effective use of current investments in the public health workforce and (2) planning for workforce surge for future pandemics? Specifically, what resources (such as toolkits, planning guides, and models), programs, and partnerships can the U.S. government provide that will support state and local preparedness for a future pandemic and staffing surges during a pandemic?