# Abbreviations

ASTHO: Association of State and Territorial Health Officials
CDC: Centers for Disease Control and Prevention
CEFO: Career Epidemiology Field Officer program
COVID-19: coronavirus disease 2019
CBO: community-based organization
CSTE: Council of State and Territorial Epidemiologists
EIS: Epidemic Intelligence Service fellowship program
FTE: full-time equivalent position
MRC: Medical Reserve Corps
NACCHO: National Association of County and City Health Officials
PHAP: Public Health Associate Program
PHEP: Public Health Emergency Preparedness cooperative agreement
PH-WINS: Public Health Workforce Interest and Needs Survey
STLT: state, tribal, local, and territorial