# Acknowledgements

Many people at ASPE contributed to this project, including Oluwarantimi Adetunji, Trinidad Beleche, and Zeid El-Kilani. ASPE also acknowledges research and analytical support from the RAND Corporation.

This communication was printed, published, or produced and disseminated at U.S. taxpayer expense.