# 7 REFERENCES

3 Axis Advisors, 2023. Estimates of U.S. Brand Drug Commercial Net Prices. [Online] Available at: https://static1.squarespace.com/static/5c326d5596e76f58ee234632/t/63eaf7810ade4918ae2e6520/1676343172537/3AA+Understanding+VA+Pricing+Report+0223.pdf
46brooklyn, 2024. This Is The Way…To Analyze Changes in Brand Drug List Prices. [Online] Available at: https://www.46brooklyn.com/branddrug-boxscore
American Academy of Professional Coders, n.d. HCPCS Codes Lookup. [Online] Available at: https://www.aapc.com/codes/hcpcs-codes-range/ [Accessed 2024].
American Hospital Association, 2023. Fact Sheet: The 340B Drug Pricing Program. [Online] Available at: https://www.aha.org/fact-sheets/fact-sheet-340b-drug-pricing-program#:~:text=Section%20340B%20of%20the%20Public,to%2050%25%20in%20pharmaceutical%20purchases.
Blalock, E., 2022. Measuring the Relative Size of the 340B Program, s.l.: Berkeley Research Group, LLC.
Bosworth, A. ., 2023. Changes in the List Prices of Prescription Drugs, 2017-2023 (Issue Brief No. HP-2023-25), Washington, DC: Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services.
Cardinal Health Specialty Solutions, 2020. Discover the value of joining a GPO. [Online] Available at: https://www.cardinalhealth.com/content/dam/corp/web/documents/literature/cardinal-health-value-of-a-gpo.pdf [Accessed 2024].
Cardinal Health, 2024. Biosimilars Landscape, s.l.: s.n.
Centers for Medicare & Medicaid Services, 2020–2022. ASP Pricing Files. [Online] Available at: https://www.cms.gov/medicare/payment/part-b-drugs/asp-pricing-files [Accessed 2024].
Centers for Medicare & Medicaid Services, 2020–2022. Medicare Part B Spending by Drug Methodology, s.l.: s.n.
Centers for Medicare & Medicaid Services, 2020. Transparency in Coverage Final Rule Fact Sheet. [Online] Available at: https://www.cms.gov/newsroom/fact-sheets/transparency-coverage-final-rule-fact-sheet-cms-9915-f [Accessed 2024].
Centers for Medicare & Medicaid Services, 2023. Hospital Outpatient Prospective Payment System (OPPS): Remedy for the 340B-Acquired Drug Payment Policy for Calendar Years 2018-2022 Final Rule (CMS 1793-F), s.l.: s.n.
Centers for Medicare & Medicaid Services, 2024b. Medicare Part D Spending by Drug. [Online] Available at: https://data.cms.gov/summary-statistics-on-use-and-payments/medicare-medicaid-spending-by-drug/medicare-part-d-spending-by-drug/data [Accessed 2024].
Centers for Medicare & Medicaid Services, 2024c. Medicare Part B Spending by Drug. [Online] Available at: https://data.cms.gov/summary-statistics-on-use-and-payments/medicare-medicaid-spending-by-drug/medicare-part-b-spending-by-drug/data [Accessed 2024].
Centers for Medicare & Medicaid Services, 2024. Medicaid Drug Rebate Program (MDRP). [Online] Available at: https://www.medicaid.gov/medicaid/prescription-drugs/medicaid-drug-rebate-program/index.html [Accessed 2024].
Clark, B. & Puthiyath, M., 2022. The Federal 340B Drug Pricing Program: What It Is, and Why It’s Facing Legal Challenges, s.l.: The Commonwealth Fund.
Congressional Budget Office, 2021. A Comparison of Brand-Name Drug Prices Among Selected Federal Programs, s.l.: s.n.
Dolan, R., 2019. Understanding the Medicaid Prescription Drug Rebate Program, s.l.: KFF.
Fein, A. J., 2024. The Top Pharmacy Benefit Managers of 2023: Market Share and Trends for the Biggest Companies—And What’s Ahead. [Online] Available at: https://www.drugchannels.net/2024/04/the-top-pharmacy-benefit-managers-of.html [Accessed 2024].
Feng, K. ., 2024. Patient Out-of-Pocket Costs for Biologic Drugs After Biosimilar Competition. JAMA Health Forum, 5(3), p. e235429.38551589
Freed, M. ., 2024. Medicare Advantage in 2024: Enrollment Update and Key Trends. [Online] Available at: https://www.kff.org/medicare/issue-brief/medicare-advantage-in-2024-enrollment-update-and-key-trends/ [Accessed 2024].
Health Resources & Services Administration, 2020. Duplicate Discount Prohibition. [Online] Available at: https://www.hrsa.gov/opa/program-requirements/medicaid-exclusion
Health Resources & Services Administration, 2024. 340B Drug Pricing Program: Program Requirements. s.l.:s.n.
Health Resources & Services Administration, 2024. Office of Pharmacy Affairs 340B OPAIS. [Online] Available at: https://340bopais.hrsa.gov/CoveredEntitySearch/000001477 [Accessed 2024].
Hernandez, I., San-Juan-Rodriguez, A., Good, C. B. & Gellad, W. F., 2020. Changes in List Prices, Net Prices, and Discounts for Branded Drugs in the US, 2007-2018. JAMA, 323(9), pp. 854–862.32125403
Internet Archive, 2024. Wayback Mcahine. [Online] Available at: https://archive.org/ [Accessed 2024].
Knox, R. P. ., 2023. Outcomes of the 340B Drug Pricing Program. JAMA Health Forum, 4(11), p. e233716.37991784
Martin, R. & Karne, H., 2024. The 340B Drug Discount Program Grew to $124B in 2023, s.l.: IQVIA.
Maryland Department of Health, n.d. National Drug Code (NDC) Conversion Table. [Online] Available at: https://health.maryland.gov/phpa/OIDEOR/IMMUN/Shared%20Documents/Handout%203%20-%20NDC%20conversion%20to%2011%20digits.pdf [Accessed 2024].
Medicaid.gov, 2020–2022. Medicaid Drug Rebate Program Data. [Online] Available at: https://www.medicaid.gov/medicaid/prescription-drugs/medicaid-drug-rebate-program/medicaid-drug-rebate-program-data/index.html [Accessed 2024].
Medicaid.gov, 2024. Unit Rebate Amount Information. [Online] Available at: https://www.medicaid.gov/medicaid/prescription-drugs/medicaid-drug-rebate-program/unit-rebate-amount-calculation/index.html#Statutory
MedPAC, 2024. Report to the Congress: Medicare Payment Policy (Hospital inpatient and outpatient services), s.l.: s.n.
Mehr, S., 2024. Sustaining competition for biosimilars on the pharmacy benefit: Use it or lose it. J Manag Care Spec Pharm, 30(6), pp. 600–603.38824633
Miller, G., Hill, S. & Ding, Y., 2019. Retail Drug Prices, Out-of-Pocket Costs, and Discounts and Markups Relative to List Prices: Trends and Differences by Drug Type and Insurance Status, 2011 to 2016, s.l.: Agency for Healthcare Research and Quality.
Mulcahy, A. & Kareddy, V., 2021. Prescription Drug Supply Chains: An Overview of Stakeholders and Relationships, s.l.: RAND Corporation.
Mulligan, K., 2021. The 340B Drug Pricing Program: Background, Ongoing Challenges and Recent Developments, s.l.: USC Schaeffer.
Nguyen, X., Olsen, T., Sheingold, S. & Delew, N., 2023. Medicare Part B Drugs: Trends in Spending and Utilization, 2008-2021 (Issue Brief No. HP-2023-17), Washington, DC: Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services.
Oakley, M., 2022. How do GPOs Make Money?. [Online] Available at: https://una.com/resources/article/how-do-gpos-make-money/ [Accessed 2024].
Office of Inspector General HHS, 2024b. Biosimilars Have Lowered Costs for Medicare Part B and Enrollees, but Opportunities for Substantial Spending Reductions Still Exist, s.l.: s.n.
Office of Inspector General HHS, 2024. Biosimilar Cost and Use Trends in Medicare Part B, s.l.: s.n.
Pew, 2017. Drug Spending Glossary. [Online] Available at: https://www.pewtrusts.org/en/research-and-analysis/fact-sheets/2017/09/drug-spending-glossary
Pritchett, J., 2023. Biosimilars in the United States 2023-2027: Competition, Savings and Sustainability, s.l.: IQVIA Institute for Human Data Science.
ResDAC, 2020–2022. Outpatient (Fee-for-Service). [Online] Available at: https://resdac.org/cms-data/files/op-ffs [Accessed 2024].
ResDAC, 2020–2022. TAF Other Services File. [Online] Available at: https://resdac.org/cms-data/files/taf-ot [Accessed 2024].
ResDAC, 2024. Carrier (Fee-for-Service). [Online] Available at: https://resdac.org/cms-data/files/carrier-ffs [Accessed 2024].
Robinson, J. C., Whaley, C. & Dhruva, S. S., 2024. Hospital Prices for Physician-Administered Drugs for Patients with Private Insurance. The New England Journal of Medicine, Volume 390.
Roehrig, C. & Turner, A., 2022. Projections of the Non-retail Prescription Drug Share of National Health Expenditures, s.l.: Altarum.
Scott, J., Voorhees, J. & Angel, M., 2014. GPOs: Helping to Increase Efficiency and Reduce Costs for Healthcare Providers and Suppliers, Alexandria, VA: Applied Policy.
Seeley, E., 2022. The Impact of Pharmaceutical Wholesalers on U.S. Drug Spending, s.l.: The Commonwealth Fund.
Sood, N., Ribero, R., Ryan, M. & Van Nuys, K., 2020. The Association between Drug Rebates and List Prices, s.l.: USC Schaeffer Leonard D. Schaeffer Center for Health Policy & Economics.
U.S. Bureau of Labor Statistics, 2024. Consumer Price Index for All Urban Consumers: Medical Care in U.S. City Average. [Online] Available at: https://fred.stlouisfed.org/series/CPIMEDSL [Accessed 2024].
U.S. Department of Health and Human Services, O. o. I. G., n.d. Fraud & Abuse Laws. [Online] Available at: https://oig.hhs.gov/compliance/physician-education/fraud-abuse-laws/ [Accessed 2024].
U.S. Department of Veterans Affairs, Office of Procurement, Acquisition and Logistics, 2023. Pharmaceutical Prices: Pricing Data. s.l.:s.n.
U.S. Food & Drug Administration, 2024. Purple Book Database of Licensed Biological Products. [Online] Available at: https://purplebooksearch.fda.gov/downloads [Accessed 2024].
U.S. Government Accountability Office, 2010. Group Purchasing Organizations: Services Provided to Customers and Initiatives Regarding Their Business Practices, s.l.: s.n.