# ACKNOWLEDGEMENTS

We gratefully acknowledge Trinidad Beleche (HHS/OS/ASPE), Oluwarantimi Adetunji (HHS/OS/ASPE), and Andrea Monge (HHS/OS/ASPE) for their leadership, guidance, and input throughout this study. We also thank Dobson | DaVanzo for their expertise, processing, and analysis of the CMS claims data and their contributions to the description of those data sources and methods. We would like to acknowledge all federal experts for providing guidance and/or review of the study report and findings, including Katherine Bent (HHS/OS/ASPE), Kathleen Miller (HHS/OS/ASPE), and Rebecca Haffajee (HHS/OS/ASPE). We are grateful to Dr. Neeraj Sood (Sol Price School of Public Policy, University of Southern California) for his thorough review of the draft report, and we thank Andreas Lord (ERG) for his detailed review.