# EXECUTIVE SUMMARY

## ES.1 OVERVIEW AND METHODOLOGY

The U.S. supply chain for provider-administered outpatient drugs involves several entities, including drug manufacturers, wholesalers, healthcare providers (e.g., outpatient facilities, hospital pharmacies, doctor’s offices, and standalone clinics), group purchasing organizations (GPOs), payers, and beneficiaries. For Medicare Part B and Medicaid beneficiaries, negotiations among these supply chain entities are highly complex and can involve a variety of price benchmarks combined with private negotiation. Drug manufacturers develop and sell finished drug products to wholesalers, which distribute those drugs to providers. Healthcare providers administer the drug to the beneficiary and bill the provider or healthcare plan for the cost of the drug. The patient or beneficiary pays coinsurance, which, for Part B drugs, is generally 20 percent of the drug’s cost. GPOs negotiate lower net sales prices with manufacturers and wholesalers, which they offer to providers, effectively pooling the providers’ purchasing power while giving manufacturers and wholesalers access to large national contracts. Net sales prices are typically confidential, as are the discounts and rebates shared among supply chain entities. Most supply chain entities are paid based on a percentage of the list price, which sometimes incentivizes the utilization of expensive brand name drugs and original biologics. These misaligned incentives, along with lack of pricing transparency, contribute to increasing drug costs in the United States. It is important to understand how net spending by payers and beneficiaries is distributed across the supply chain entities, the margins that pharmaceutical supply chain intermediaries earn, and how these vary by the characteristics of individual drugs.

In this report, we used data from IQVIA, the Centers for Medicare & Medicaid Services (CMS), the U.S. Department of Veterans Affairs (VA), and the U.S. Food & Drug Administration (FDA) to estimate the total net spending by payers and beneficiaries on separately billable outpatient drugs administered by healthcare professionals to Medicare Part B and Medicaid beneficiaries in outpatient and physician office settings. We modeled these payments by payers and beneficiaries as initial monetary inputs into a closed system of supply chain entities. These monetary inputs get distributed to supply chain members through complex flows of payments, chargebacks, rebates, etc. among those entities. By estimating these flows on a per-drug basis, we examined the share of payer and beneficiary net spending that is captured by each supply chain entity and the margins of the primary intermediaries, namely wholesalers and providers, from 2020 through 2022.^1^ We also evaluated how retained shares of net spending and margins varied by a drug’s primary therapeutic area, and we also compared on other characteristics like whether the drug or product is in a competitive or noncompetitive market, is a small molecule generic or a small molecule brand, is a biosimilar biologic or an original biologic, primarily treats acute or chronic conditions, and is sold at a 340B-discounted price or a non-discounted price. For Medicare drug sales, we accounted for the fact that 340B discounts are only available to some providers on certain drug units.^2^ For Medicaid drug sales, we estimated the rebate paid by manufacturers to the Medicaid Drug Rebate Program.

The target population includes all payments made on behalf of Medicare Part B or Medicaid beneficiaries on separately payable provider-administered outpatient drugs. While the focus is on beneficiaries of public programs, to avoid underestimating the margins of supply chain entities, we included all payments made on behalf of these beneficiaries by the public payer, other payers (e.g., supplemental insurance), and beneficiaries themselves. We excluded groups of drugs with no sample data at all (mostly miscellaneous drugs or vaccines). This removed 12.3 percent and 27.6 percent of gross spending on Part B and Medicaid beneficiaries from the study population, respectively. The study population covered $113.9 billion and $19.9 billion in gross spending on Part B and Medicaid beneficiaries, respectively, across all three study years (2020 to 2022).^3,4^ Our final sample included 2,117 drugs, which we defined as unique 9-digit National Drug Codes (NDCs). The sample covered 29.3 percent ($33.4 billion) and 27.1 percent ($5.4 billion) of the study population’s gross spending on Part B and Medicaid beneficiaries, respectively.

## ES.2 KEY FINDINGS

Manufacturers retained the vast majority of payers and beneficiaries’ total net spending, followed by providers, then wholesalers, and lastly GPOs. Providers’ share of net spending increased the most from 2020 to 2022. Manufacturers retained 74 percent to 76 percent of net spending, depending on the year, which amounted to $31 billion to $33 billion dollars per year (see Figure ES-1).^5,6^ Providers retained 20 percent to 22 percent of net spending, which equated to $9 billion to $10 billion per year. This margin made up between 19 and 22 percent of providers’ net sales (see Figure ES-2). They were followed by wholesalers, which retained 3 percent to 4 percent ($1 billion to $2 billion per year), at a margin percentage of 3 percent to 5 percent. GPOs retained 1 percent of total net spending ($465 million to $500 million per year). The large share that manufacturers retained is related to drug use patterns. Between 2020 and 2022, most spending was on provider-administered drugs with no competition in the market, and manufacturers that are the sole supplier of a market have more capability to act as price-setters. However, providers saw the largest percentage increase in retained share of net spending from 2020 to 2022, at 12.5 percent. Most of the growth in net spending over this period was due to a rise in net spending on 340B-discounted drugs, which providers retained much higher shares of compared to net spending on non-340B-discounted drugs. Providers also retained more than their average on certain drug groups, including small molecule generics, on which they retained the majority of net spending (57 percent to 62 percent), and oncology drugs (21 percent to 24 percent), which had by far the highest spending of the therapeutic areas.

Net spending by payers and beneficiaries was roughly constant for the specific drug units that did not receive 340B discounts but increased 20 percent for the drug units sold at 340B-discounted prices. These 340B-discounted drug sales earned healthcare providers roughly twice the margins, on average from 2020 to 2022, compared to non-340B-discounted drug sales.^7,8^ Overall, net spending rose from $42 billion in 2020 to $45 billion in 2022, and all of this increase went toward 340B drug spending, which rose from $13 billion in 2020 to $16 billion in 2022. Under the 340B program, eligible safety-net providers acquire some drugs at discounted prices, which generate higher margins for those providers. In 2020 and 2021, providers’ margin percentages on 340B-discounted drugs were 58 percent and 81 percent higher, respectively, than their margin percentages on non-340B-discounted drugs. In 2022, this increased substantially, with providers earning roughly two and half times the margin percentage on 340B-discounted drugs compared to non-340B-discounted drugs. This increase was likely due to the 2022 reversal of a CMS rule that had been in effect since 2018, which lowered providers’ reimbursements on 340B-discounted drugs from the average sales price (ASP) plus 6 percent to ASP minus 22.5 percent. The reversal of this rule in 2022 caused healthcare providers’ reimbursements on 340B-discounted units to increase by roughly 37 percent from their then-current values, as Medicare Part B payments are primarily based on published CMS reimbursement rates. There was almost certainly not a commensurate increase in providers’ acquisition costs for these drugs, because 340B-discounted drug acquisition costs are calculated using a federally mandated formula. Our findings suggest that, even though this 2018 CMS rule likely reduced providers’ margins on 340B drug sales in 2020 and 2021, providers still earned larger margin percentages on 340B-discounted drugs than non-340B-discounted drugs during those years, before the rule was reversed.

Net spending on provider-administered outpatient drugs is dominated by original biologics with no market competition, which tend to be more expensive than small molecule drugs. Biologics made up only 16 percent of the unique drugs (i.e., 9-digit NDCs) in our sample yet accounted for 84 percent of all net spending in the United States from 2020 to 2022. Of the biologics reimbursed in this setting, 86 percent were original biologics with no biosimilar competition. In general, biological drugs tend to be more complex than small molecules to develop and manufacture (and more expensive to beneficiaries), which increases market entry barriers and reduces competition in biologics markets.

While manufacturers earned larger shares of net spending on small molecule brands and original biologics than on small molecule generics and biosimilars, this advantage was larger for original biologics than for small molecule brands. Manufacturers retained 77 percent to 80 percent of net spending (which amounted to $26 billion to $28 billion) on original biologics, compared to 61 percent to 67 percent ($3.4 billion to $3.9 billion) on small molecule brands. The fact that original biologics generated more value per dollar of net spending than small molecule brands is partly due to original biologics being less likely to experience market competition (for several reasons). For example, biosimilars can face higher barriers of entry than generic small molecule drugs depending on the product complexity, the patent landscape, and factors that impact uptake and utilization. In addition, while the number of approved biosimilar products is increasing, the abbreviated approval pathway for biosimilars was created in 2015, compared to 1984 for small molecule generics, which at least partly accounts for the much smaller number of approved biosimilars compared to approved generics.

Providers retained over half of payer and beneficiary net spending on small molecule generics. In almost all cases, we found that manufacturers retained the majority of net spending on provider-administered outpatient drugs. For small molecule generics, however, providers retained a larger share than manufacturers. Total net spending on small molecule generics ranged from $1.1B to $1.2B—the lowest net spending in dollar terms of all the drug groups we analyzed. Of this total, providers earned 57.0 percent to 61.8 percent ($629 million to $718 million), compared to 34.2 percent to 39.0 percent for manufacturers ($398 million to $430 million), 3.1 percent to 3.3 percent for wholesalers ($36 million to $39 million), and 0.7 percent for GPOs ($8 million).

Our results are consistent with others’ findings that biosimilars are effective at reducing spending. Between 2020 and 2022, the number of biosimilars in U.S. markets doubled, and they continued to gain market share in the United States. Yet net spending on competitive biologics^9^ decreased by 36 percent—even as spending rose for biologics in general.^10^ This spending decline that we observed over the three-year study period is very similar to the average 36-month price reduction following biosimilar market entry, which ranges from about 13 percent to 42 percent and averages about 31 percent when using the IQVIA National Sales Perspective (NSP) invoice price metric (Pritchett, 2023) (estimated from Pritchett’s Exhibit 17). Moreover, wholesalers and providers earned more on noncompetitive biologics than competitive biologics. Wholesalers earned margins of 4 percent to 5 percent on competitive biologics ($150 million to $220 million), compared to 3 percent to 4 percent on noncompetitive biologics ($840 million to $1.09 billion). Providers earned margins of 22 percent to 27 percent ($0.99 billion to $1.84 billion) on competitive biologics compared to 15 percent to 18 percent ($4.17 billion to $6.41 billion) on noncompetitive biologics. While wholesalers and providers had higher margin percentages on competitive biologics, the dollar amount was lower, mainly because there are many more non-competitive biologics markets.

Net spending grew 6.2 percent over the study period, which coincided with the COVID-19 pandemic. The pandemic likely had different effects on drug use patterns and spending based on a drug’s therapeutic class. Medicare Part B covered the COVID-19 vaccine, as well as certain drugs for treating COVID-19, including Remdesivir. These drug products probably saw increased utilization between 2020 and 2022. However, there was likely a decrease in spending on drugs used in certain non-essential procedures, many of which were postponed to reduce the burden on healthcare facilities during this time.

Data limitations and simplifications in the model impact output estimates. We did not observe actual prices on several flows, including wholesaler net acquisition costs, 340B-discounted prices, reimbursement rates paid by Medicare Part B in outpatient settings, and reimbursement rates paid by Medicaid in any setting. We estimated these costs using other data sources. In addition, we modeled the supply chain as a closed system and estimated drug flows throughout the system by applying drug utilization data as measured by payers. This does not account for unsold products that may expire and generate additional losses for the supplier or provider. As another limitation, the single distribution channel of drug acquisition from manufacturer to wholesaler to provider to payer is also a simplification, as providers sometimes purchase drugs directly from the manufacturer. Moreover, we only measured payments triggered by a drug reimbursement. We did not quantify payments that are not made on a per-drug basis, including per-member payments to Managed Care Organizations (MCOs), Medicare Administrative Contractors (MACs), and annual membership fees that providers may pay to GPOs.

Figure ES-1 Distribution of Payer-Beneficiary Net Spending to Supply Chain, by Drug Groups, 2020–2022

Note: Some data columns for GPOs may be too small to see at this scale.

The figure contains several stacked bar plots showing percentage of net spending retained each year, with colors indicating supply chain entities. The plots show spending retained by each entity on all drugs, and then split out to show each of the following: 340B-discounted versus non-340B-discounted drugs, original biologics versus biosimilars, small molecule brands versus small molecule generics, noncompetitive biologics vs competitive biologics, and noncompetitive small molecules versus competitive small molecules. For all drug groups and subgroups except small molecule generics and competitive small molecules, manufacturers retain the largest share of spending, followed by providers, then wholesalers, then GPOs. For those two groups, providers retain more than manufacturers.

Figure ES-2 Providers and Wholesalers’ Margins, by Drug Group, 2020–2022

Note: Manufacturer margins are not estimated because they do not generally pay an acquisition cost for the finished drug product, and we did not quantify their raw ingredient costs. GPO margins are not estimated because they generally do not pay or get paid for the full cost of the drug and thus do not have net acquisition costs or net sales prices.

The figure contains several grouped bar plots showing margin percentages each year, with colors indicating the supply chain entity (of providers and wholesalers). The plots show spending retained by each entity on all drugs, and then split out to show each of the following: 340B-discounted versus non-340B-discounted drugs, original biologics versus biosimilars, small molecule brands versus small molecule generics, noncompetitive biologics vs competitive biologics, and noncompetitive small molecules versus competitive small molecules. Provider margins are generally between 10 and 30 percent for most drug groups, and wholesaler margins are below 5 percent for most groups.

1 Margins, one primary focus of the report, represent the portion of revenue from pharmaceutical sales retained after accounting for acquisition costs, discounts, and rebates that impact either the acquisition cost or the sales price. Margins were not calculated for manufacturers because we did not quantify manufacturers’ costs of goods for the drug. We did not estimate margins of GPOs because they do not make payments and are not paid for the full cost of the drug.

2 The 340B program under Medicare allows eligible “safety-net” providers, which serve low-income and underserved populations, to purchase drugs at a discounted rate. See discussion of 340B pricing in section 2.

3 All monetary values are expressed in 2023 dollars.

4 Our results are expressed throughout the study in terms of net spending, which is equal to gross spending less the estimated Medicaid rebates paid by manufacturers back to the payer.

5 It should be noted that we did not account for manufacturers’ costs of raw materials or research and development.

6 The sample covers $38.7 billion in gross spending and $37.7 billion in net spending from 2020 to 2022, which include payments by Medicare Part B and Medicaid. In section ES.2, we present weighted results, which scale up the estimates from the sample to the full study population. From 2020 to 2022, the weighted gross spending in the study population was $133.8 billion and the weighted net spending was $129.9 billion.

7 We use the terms “340B-discounted drug” and “non-340B-discounted drug” to identify the specific drug units or sales that received discounted pricing under the 340B program. It should be noted that a single drug product would generally have some sales that are 340B-discounted and others that are not. Our analysis accounts for this as well as the fact that not all drug units that 340B facilities acquire are eligible for 340B discounts (in particular, those administered to Medicaid beneficiaries).

8 It should be noted that 340B providers comprise “health care organizations that care for many uninsured and low-income patients. These organizations include federal grantee organizations and several types of hospitals, including critical access hospitals (CAHs), sole community hospitals (SCHs), rural referral centers (RRCs), and public and nonprofit disproportionate share hospitals (DSH) that serve low-income and indigent populations. … Hospitals use 340B savings to provide, for example, free care for uninsured patients, offer free vaccines, provide services in mental health clinics, and implement medication management and community health programs.” (American Hospital Association, 2023)

9 A competitive biologic includes any original biologic that faces biosimilar competition as well as all of its marketed biosimilars. An original biologic listed as the reference product in one or more approved 351(k) applications but that does not yet have competition (e.g., due to delayed biosimilar market entry) is considered a noncompetitive biologic.

10 Most biosimilars in our sample are oncology drugs. While some medical procedures and clinical services were canceled or delayed during the pandemic, our analysis suggests that spending on oncology drugs continued to rise from 2020 to 2022.