# 6 CONCLUSION

This study combines prices from each level of the supply chain, tracking the flows and payments of individual drugs as they are acquired, sold, or negotiated by manufacturers, wholesalers, GPOs, providers, and payers. Using these drug-level price estimates, which account for 340B discounts, we estimated the share of net spending that each supply chain entity retains. By comparing the net acquisition cost to the net sales price, we also calculated the margins earned by wholesalers and providers. We found that spending on provider-administered outpatient drugs in Medicare Part B and Medicaid is dominated by original biologics, small molecule brands, and drugs or products with no competition in the market. Consequently, manufacturers—which have more negotiating power than other supply chain entities when they are the exclusive suppliers of a market—retained almost three-quarters of total drug spending. While manufacturers earned more on drugs that do not face competition, providers and wholesalers earned higher margin percentages on drugs that do face competition. Providers’ margin percentages were also significantly higher for 340B-discounted drugs than for non-340B-discounted drugs—more than double in 2022. From 2020 to 2022, payer and beneficiary net spending on physician-administered drugs increased, but the relative distribution of these payments to the various supply chain entities did not change substantially. To the extent that increased spending is due to rising list prices, no single supply chain entity benefited more than the others from the growth in drug prices.

Despite the high spending on drugs and biological products with no competition, our results suggest that biosimilars have been very effective, when available, at generating savings for Medicare and Medicaid. Between 2020 and 2022, net spending in competitive biologic markets declined even as the number of biosimilars marketed in the United States doubled. The downward pressure on the reference product’s price was great enough to reduce overall net spending in these markets by about 36 percent from 2020 to 2022.