# 5 DISCUSSION

Across all drugs, net spending by payers and beneficiaries increased by 6.2 percent from 2020 to 2022, but the growth was not disproportionately captured by any one supply chain entity. Instead, we observed a relatively consistent distribution of overall net spending to the supply chain entities from 2020 to 2022. This contrasts with retail drugs, where some research has found that rising list prices are accompanied by constant or decreasing manufacturer net prices (Hernandez, et al., 2020). Hernandez et al. note that net prices of retail drugs were stable between 2015 and 2018 despite list prices continuing to rise (2020). This suggests that rising prices of retail drugs may be driven primarily by rising margins of intermediaries rather than those of manufacturers. We did not observe such an effect for the provider-administered outpatient drug setting in our study. On the contrary, the distribution of net spending across the supply chain entities was relatively stable for providers and decreased slightly for wholesalers.

Manufacturers retained approximately three-quarters of overall net drug spending, and this percentage was relatively constant from 2020 to 2022. The fact that manufacturers retain the vast majority of net spending is partly because we have not separated the net spending disbursed to finished drug manufacturers from that disbursed to raw ingredient manufacturers. Nonetheless, the high share of retained spending that manufacturers capture demonstrates their strong market position to act as price setters, which is partly attributable to the fact that noncompetitive biologics dominate provider-administered outpatient drug markets, accounting for over 80 percent of net spending. In our sample, 91.4 percent of biologics were original biologics, and on these drugs, manufacturers retained almost fourth-fifths of all net spending from 2020 to 2022. In comparison, only 19.6 percent of small molecules in our sample were brand drugs. Original biologics were also much less likely than small molecule brand drugs to face competition in the market. Only 14.9 percent of net spending on biologics was in competitive markets, compared to 37.4 percent for small molecules.

One major difference from the retail drug market is that pharmacy benefit managers (PBMs) are not generally involved in managing benefits for the provider-administered drugs that we studied. In the retail drug market, PBMs create formularies (among other tasks), which dictate beneficiary copays and thus greatly influence the specific drug a patient chooses. The PBM market is highly concentrated, with three PBMs processing roughly 80 percent of all claims in 2023 (Fein, 2024). This gives PBMs broad power to negotiate lower prices from other supply chain members, including manufacturers, since formulary exclusion by just one of the big three PBMs can severely reduce a product’s utilization and sales, as was seen with the initial rollout of Humira biosimilars (Mehr, 2024). PBMs often achieve price reductions by negotiating rebates that manufacturers agree to pay when their drug is used by beneficiaries. PBMs then share these rebates with the payer in part or in whole.

The absence of PBMs from physician-administered drug reimbursements may have two effects. First, other intermediaries appear to capture earnings that would have gone to PBMs—including healthcare providers, which are able to pool their purchasing power through GPOs. At the same time, however, the reliance on GPOs to achieve cost savings imposes a limit on providers’ ability to act as price setters, particularly compared to PBMs, which are far more consolidated than healthcare providers. For example, in an outpatient setting, each provider (e.g., including hospital outpatient pharmacies) may create its own formulary, increasing the opportunities for manufacturers to compete for favorable placement on different providers’ formularies without the same risk of large-scale exclusion that exists in retail drug markets. We found that there was consistency from 2020 to 2022 in the distribution of net spending to supply chain members, which suggests that there was a degree of stability in the dynamics between supply chain members. While spending per beneficiary has increased more rapidly in Part B than in Part D (Nguyen, et al., 2023), our findings suggest that this is not the result of any single supply chain member gaining a foothold that might allow them to extract higher margins.

In markets where biosimilars have entered, the increased competition reduced net spending over the study period. Biosimilars offer lower-priced alternatives, which tend to be 15 to 35 percent less expensive than their reference products (Feng, et al., 2024).^42^ Increased market competition leads to lower prices of the reference product, which in some cases are still declining three years after biosimilar entry (Office of Inspector General HHS, 2024). During our study period, competitive biologic markets generally grew in terms of quantity sold, patient access, the number of biosimilar competitors, and the number of competitive biologic markets. A total of 13 new biosimilars launched between 2020 and 2022, doubling the number of biosimilar products marketed in the United States (Cardinal Health, 2024).^43^ We found that total net spending on biosimilars rose by 34.0 percent during the study period. Despite this increase in biosimilar spending and use, the net effect of their market entry was a 36.4 percent decrease in net spending on all competitive biologics, including reference products and their biosimilars. This suggests that the total growth in biosimilar spending was more than offset by the savings on reference products as their prices dropped in response to the competition. The 36.4 percent spending decline we observed over the three-year study period is very similar to the average 36-month price reduction following biosimilar market entry, which has ranged from about 13 percent to 42 percent and averages about 31 percent when using the IQVIA NSP invoice price metric (Pritchett, 2023) (estimated from Pritchett’s Exhibit 17). While this supports the notion that biosimilars are effective at lowering net spending, they are not yet being fully exploited. The Office of Inspector General (OIG) at the U.S. Department of Health and Human Services (HHS) found that, in 2021, “Part B and enrollee spending on [reference] biologics could have decreased by $179 million, or 4 percent, if more affordable biosimilars had been used as frequently as the most-used biosimilars” (Office of Inspector General HHS, 2024b).

Manufacturers have more market power to set prices of noncompetitive drugs or products for which they are the exclusive supplier, and we found that they retained a larger proportion of payer and beneficiary spending on those drugs. In contrast, our analysis suggests that providers—and wholesalers to a lesser extent—had more market power to act as price setters on competitive drugs or products, which earned them higher margin percentages. On competitive small molecule drugs, providers’ margin percentages were almost double what they were on noncompetitive small molecules. Between providers and wholesalers (the two intermediaries whose margins we quantified), providers tended to have higher margin percentages. Providers even retained over half of payer and beneficiaries’ net spending on generic small molecule drugs and over half on competitive small molecule drugs. The large gap between wholesalers and providers may be partly due to 340B discounts that providers receive, but even on non-340B-discounted units, providers had roughly five times the margin percentages of wholesalers, on average.

Providers’ margins are affected by the 340B program, and they retained about twice as much of net spending on 340B-discounted drugs than on non-340B-discounted drugs. In particular, we estimate that providers retained 27.7 percent to 36.7 percent on 340B-discounted drugs, compared to 14.5 percent to 18.0 percent on non-340B-discounted drugs. In another study of provider margins, Robinson et al. (2024) found that hospitals eligible for 340B discounts retained 64.3 percent of private insurers’ drug spending, compared to 44.8 percent by hospitals not eligible for 340B discounts and 19.1 percent by independent physician practices (2024). These estimates are substantially higher than our own, but their analysis was limited to claims covered by non-federal payers (employment-based or individually purchased insurance) while we only considered Medicaid and Medicare claims. They also used a much smaller sample of 57 drugs, many of which were being “targeted for cost-reduction strategies by a large national insurer.” Another major difference is that Robinson et al. estimated provider acquisition costs using the average sales price published by CMS, while assuming 340B-eligible hospitals receive a 35 percent discount on acquisition costs. In contrast, our acquisition costs are estimated using IQVIA NSP data, which is based on actual invoices to providers.

Provider margins on 340B-discounted drugs also grew substantially in 2022 when a 2018 CMS rule regarding 340B reimbursement rates was revoked. In 2020 and 2021, providers’ margin percentages were 10.3 to 12.5 percentage points higher on 340B-discounted drugs than on non-340B-discounted drugs. This corresponded to 59.5 percent to 81.1 percent higher margin percentages. In 2022, the gap between providers’ margins on 340B-discounted drugs versus non-340B-discounted drugs rose to 22.9 percentage points—a 166.3 percent difference. This coincided with a change in CMS’s 340B reimbursement rates. From Quarter 1 (Q1) of 2018 through Q3 of 2022, a rule was in effect that reduced providers’ reimbursements on 340B-discounted units from ASP plus 6 percent to ASP minus 22.5 percent (Centers for Medicare & Medicaid Services, 2023). In Q4 of 2022, the 340B drug reimbursement rate was changed back to ASP plus 6 percent, after the rule implementing these rate changes was deemed invalid.

Notably, even before the CMS rule was revoked, we still found that providers earned substantially higher margin percentages on 340B drug sales than on non-340B drug sales. From 2020 to 2021, there was a 5.5 percent growth in 340B drug spending, which outpaced growth in non-340B drug spending (3.3 percent). This may be due to expansion of the 340B program. For example, from 2000 to 2020, there was a roughly six-fold increase in the number of 340B covered sites. From 2020 to 2021, the number of covered sites rose by roughly 3.7 percent (Mulligan, 2021) (estimated from Mulligan’s Figure 3).

It should be noted that discounted acquisition costs of drugs are intended to create opportunities for 340B facilities to offer additional services to at-risk patients. The rapid expansion of the 340B drug program has led to greater scrutiny in recent years, and some efforts have been made to compare outcomes at 340B facilities to non-340B facilities. While this type of analysis is beyond the scope of our study, a scoping review by Knox et al. (2023) found “mixed evidence … on how covered entities used their 340B revenue, with some studies suggesting use to expand health care services for low-income populations and others to acquire physician practices and open sites in higher-income neighborhoods.”

Regarding therapeutic areas, about half of net spending was on oncology drugs, which tend to be more expensive than drugs in other therapeutic areas. From 2020 to 2022, oncology drugs made up 46.6 percent to 50.0 percent of total annual spending.^44^ Total net spending on oncology drugs increased steadily over the study period, rising from $19.5 billion in 2020 to $22.2 billion in 2022—an increase of $2.7 billion or 13.8 percent. Of this spending increase, $1.1 billion or 42.2 percent was captured by providers, which is twice their average share of net spending on oncology drugs from 2020 to 2022.

The fact that oncology spending growth (13.8 percent) outpaced overall spending growth (6.2 percent) may be due, in part, to the COVID-19 pandemic. During the pandemic, some non-essential or elective procedures and office visits were canceled or rescheduled to reduce exposure and reduce the burden on healthcare facilities. Compared to other therapeutic areas, however, oncology treatments are less likely to be delayed given the severity of the disease. From 2008 to 2021, Part B drug spending rose by 9.2 percent annually in traditional Medicare, on average (Nguyen, et al., 2023), which is 3.0 percentage points higher than what we observed from 2020 through 2022, during the COVID-19 pandemic.

Our study has several limitations. The primary limitations relate to the lack of available data on drug pricing. We did not observe wholesaler net acquisition costs and instead estimated these from the VA FSS data, which required assuming that (a) VA FSS prices are representative of payments to wholesalers, and (b) the VA FSS prices depend only on the WAC, the NSP invoice price, the drug’s brand-generic status, and the calendar year. Another limitation is that, because our analysis is focused on drug-level payment flows, we do not account for per-member fees. For this reason, we have not included profits to insurance companies, Managed Care Organizations (MCOs), or Medicare Administrative Contractors (MACs). With respect to prices, we did not have data on reimbursement rates in Medicaid or Medicare Part B physician settings. We assumed these reimbursement rates to providers were the same as for Medicare Part B outpatient settings. Similarly, we did not account for Medicare Advantage spending, which is a growing share of the Medicare market and reached over 50 percent of Medicare enrollment in 2023 (Freed, et al., 2024).

Our estimates of provider margins rely, in part, on the estimated 340B discounts. However, we did not have data for 340B-discounted prices or manufacturers’ AMPs, from which they are calculated. Our method of estimating these used IQVIA NSP data, which differs from the AMP and does not contain all rebates.^45^ We also did not account for the inflation-based component of the 340B or Medicaid unit rebate amount (URA) because, in most cases, we did not have price estimates going back to the drug’s market entry date. However, as validation, our average 340B discount can be compared with other published estimates. For each drug in our sample, we calculated the 340B-to-WAC discount and found the average of these to be 51.9 percent. In comparison, Blalock estimated that “340B prices were, on average, 59 percent lower than list prices in 2020” (Blalock, 2022). A recent IQVIA report estimated that “the average 340B discount [was] approximately 55%” as of 2023 (Martin & Karne, 2024). While our average 340B discount is relatively similar to these reported figures, the discount is larger when expressed as the total weighted sales in 340B dollars divided by the total weighted sales in WAC dollars. Using this metric, the total 340B discount according to our data is 69.5 percent—higher than the other two estimates.

As another limitation, we treated the supply chain as a closed system, which does not account for the fact that, under the buy-and-bill system, some drugs expire before they are used, which generates losses for providers that we did not quantify. Accounting for these losses would tend to reduce providers’ margins slightly. We also assumed that all units were sold through a wholesaler, which is not true in every case, as some providers purchase certain drugs directly from manufacturers. This simplification may have led to a small overestimate in the amount of net spending retained by wholesalers and a slight underestimate in manufacturers’ retained share of net spending. We made a similar assumption about GPOs and attributed an administrative fee on every drug administered by a nonprohibited 340B facility or non-340B facility. This likely overestimated the amount of net spending that GPOs retain, since not all eligible facilities participate in GPO contracts. On the other hand, we did not account for all fees that GPOs earn; for example, some GPOs charge a membership fee to participating providers, though these are not applied on a per-drug basis. We also did not account for all manufacturer price concessions, including copay assistance programs (to the extent that they are used with provider-administered drugs). Because manufacturers provide these additional discounts, their retained share of net spending may be lower than we estimated.

While our sample was large, it was a convenience sample nonetheless. Certain drugs were excluded out of necessity, and some HCPCS codes had no data and were excluded from our study population altogether. If these out-of-sample drugs differ systematically from the in-sample drugs, then this would limit the extent to which our findings can be extrapolated beyond the sample. This limitation was mitigated, however, by our large sample.

Our findings are focused on net spending and margins, but as an area of future research, it would be valuable to compare trends in spending to trends in utilization and price. In our study, we were unable to assess the extent to which increased spending (and margin dollars) are due to growing patient populations as opposed to rising drug prices. Additionally, we only considered spending on Medicare Part B and Medicaid beneficiaries, and price transparency has historically been higher in these public programs. With the implementation of the Transparency in Coverage rule, reimbursement rates by commercial providers have become publicly available (Centers for Medicare & Medicaid Services, 2020). These data are relatively new and highly useful for estimating margins on drugs administered to commercial plan beneficiaries. It would be worthwhile to assess how margins vary between public and private payer spending. Finally, our findings suggest that the 340B program generates substantially higher margins to providers. It would be interesting to evaluate the extent to which increased margins correlate with additional services at 340B facilities offer or improved health outcomes.

42 The reference product is the original biological product licensed under section 351(a), against which a proposed biosimilar product is evaluated.

43 Specifically, this includes Semglee, Avsola, Byooviz, Cimerli, Ruxience, Riabni, Trazimera, Herzuma, Ontruzant, Zirabev, Alymsys, Nyvepria, and Releuko. During 2023 and 2024, FDA approved 23 additional biosimilars, bringing the total to 63 approved biosimilars representing 18 original biologic reference products. Not all of these biosimilars have entered their markets due to ongoing patent litigation or settlement agreements.

44 Our study was not designed to estimate the number of packages sold in the full study population, as spending data was only available at the 9-digit NDC level and not the 11-digit NDC level for some drugs. However, based on unweighted estimates of sampled drugs with known package information (which cover 99.8 percent of spending in the sample), oncology drugs comprised 15.5 percent to 21.2 percent of packages sold to Medicare beneficiaries but 59.0 percent to 63.5 percent of net spending from 2020 to 2022.

45 Similarly, the IQVIA NSP invoice price would only reflect the GPO-negotiated discount if the wholesaler invoiced the provider at the discounted price. The GPO-negotiated price may not be listed on the invoice in cases where, for example, the manufacturer of the drug participates in the GPO but the wholesaler does not.