# 4 RESULTS

## 4.1 Overview of Sample

Across all three study years, the sample contained a total of 2,117 drugs, 528 HCPCS codes, and $38.7 billion in gross spending. This included 1,778 small molecule drugs ($5.6 billion in gross spending) and 339 biologics ($33.1 billion). Among small molecules, the sample contained 349 brand drugs ($5.0 billion in gross spending) and 1,429 generic drugs ($0.6 billion). The biologics in the sample included 310 original biologics ($31.3 billion in gross spending) and 29 biosimilars ($1.8 billion). Over the full study period, we observed 249 noncompetitive or single-source small molecule drugs ($4.1 billion in gross spending) and 1,538 competitive or multi-source small molecule drugs ($1.5 billion). We also observed 293 noncompetitive biologics ($27.4 billion in gross spending) and 46 competitive biologics ($5.7 billion).^35^ There were 519 oncology drugs in the sample ($23.7 billion in gross spending), compared to 1,598 drugs for other therapeutic areas ($15.0 billion). In the sample, 1,644 drugs were classified as treating acute conditions ($29.5 billion in gross spending), 467 drugs were classified as treating chronic conditions ($9.1 billion), and 6 drugs were unclassified ($0.1 billion). Table B-1 shows the characteristics of the sample for each year in the study period.

Table 2 Sample Characteristics, 2020–2022

Drug Group | Spending in Sample (Billion 2023 $) | Number of Drugs | Number of Unique HCPCS Codes
All drugs | $38.72 | 2,117 | 528
Acute drugs | $29.50 | 1,644 | 399
Chronic drugs | $9.08 | 467 | 132
340B-discounted drugs | $26.43 | 2,030 | 525
Non-340B-discounted drugs | $12.30 | 1,319 | 436
Competitive biologics (reference products and biosimilars) | $5.73 | 46 | 26
Non-competitive biologics (original biologics only) | $27.37 | 293 | 169
Multi-source small molecules | $1.49 | 1,538 | 233
Single-source small molecules | $4.13 | 249 | 150
Biosimilars | $1.81 | 29 | 17
Original biologics | $31.29 | 310 | 178
Small molecules, brand | $5.03 | 349 | 204
Small molecules, generic | $0.59 | 1,429 | 218
Oncology drugs | $23.7 | 519 | 142
Non-oncology drugs | $15.0 | 1,598 | 387

Note: Six drugs had an unclassified condition type (neither acute nor chronic). See Table B-1 for sample characteristics by year.

## 4.2 Study Population Results for All Drugs

To generate results for the entire study population, we weighted the drug-level estimates in our sample, following the procedure described in section 3.3.2 to obtain proper weights for each drug group. Hence, this section presents weighted estimates for the full study population that we derived by scaling up our sample data through appropriate weighting.

Total net spending by payers and beneficiaries grew by 6.2 percent from 2020 to 2022, rising from $41.9 billion to $44.5 billion.^36^ Across all drugs, manufacturers consistently retained the largest share of annual net spending, at 74.2 percent to 75.8 percent ($31.1 billion to $33.0 billion) depending on the year (see Figure 3). GPOs retained 1.1 percent of net spending ($465 million to $500 million), wholesalers retained 2.5 percent to 3.6 percent ($1.1 billion to $1.5 billion), and providers retained 19.8 percent to 22.2 percent ($8.6 billion to $9.9 billion). Provider margins ranged from 19.1 percent to 21.5 percent of annual net sales (see Figure 4), while wholesaler margins were substantially lower (3.2 percent to 4.5 percent).^37^ From 2020 to 2022, providers’ total dollar margins across all drugs increased by 12.5 percent, from $8.8 billion to $9.9 billion. In comparison, wholesalers’ dollar margins dropped from $1.5 billion to $1.1 billion, a decrease of 26.2 percent. Manufacturers captured $1.9 billion or 72.7 percent of the growth in net spending from 2020 to 2022, which is very similar to their average share of payer and beneficiary spending over the three years.

Figure 3 Distribution to Supply Chain of Payer-Beneficiary Net Spending on All Drugs

Note: Some data columns for GPOs may be too small to see at this scale.

Two stacked bar plots show amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year on all drugs. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Manufacturers retain the largest share, followed by providers, wholesalers, and GPOs. Total net spending increases from 2020 to 2022. See Table B-2 for all data values.

Figure 4 Providers and Wholesalers’ Margins on All Drug

Note: Manufacturer margins are not estimated because they do not generally pay an acquisition cost for the finished drug product, and we did not quantify their raw ingredient costs. GPO margins are not estimated because they generally do not pay for or receive payment for the full cost of the drug.

Two grouped bar plots show margins (in billion 2023 dollars) and margin percentage by year for all drugs. Colors on each bar distinguish between supply chain entities – providers and wholesalers. Providers have larger margins than wholesalers, with margins between 8 and 10 billion dollars. See Table B-3 for all data values.

## 4.3 Small Molecule Brands vs. Generics and Original Biologics vs. Biosimilars

### 4.3.1 Small Molecule Drugs

From 2020 to 2022, all supply chain entities earned more money (in 2023 dollars) on small molecule brands than small molecule generics (see Figure 5). Manufacturers retained 60.5 percent to 66.6 percent of payer and beneficiaries’ net spending on small molecule brands, but only 34.2 percent to 39.0 percent on small molecule generics. Providers earned a higher share of net spending on small molecule generics (57.0 percent to 61.8 percent) than on small molecule brands (29.2 percent to 35.5 percent). They also had higher margin percentages on generic small molecule drugs (see Figure 6). Wholesalers earned 1.8 percent to 3.2 percent of net spending on small molecule brands, and 3.1 percent to 3.3 percent on small molecule generics, but had slightly higher margin percentages on small molecule generics (7.3 percent to 8.1 percent) than small molecule brands (2.6 percent to 4.5 percent). Because GPO fees are based on the sales price, which is generally higher for brand drugs, GPOs earned a slightly larger share of net spending on small molecule brands (0.9 percent to 1.0 percent) than small molecule generics (0.7 percent).

Figure 5 Distribution to Supply Chain of Payer-Beneficiary Net Spending on Brand and Generic Small Molecule Drugs

Note: Some data columns for GPOs may be too small to see at this scale.

Two stacked bar plots show amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year, with two panels showing small molecule brands and small molecule generics separately in each. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Total net spending is much larger on small molecule brands than generics. Providers retain more on small molecule generics than manufacturers do, which is not the case for small molecule brands. See Table B-4 for all data values.

Figure 6 Providers and Wholesalers’ Margins on Brand and Generic Small Molecule Drugs

Note: Manufacturer margins are not estimated because they do not generally pay an acquisition cost for the finished drug product, and we did not quantify their raw ingredient costs. GPO margins are not estimated because they generally do not pay or get paid for the full cost of the drug.

Two grouped bar plots show margins (in billion 2023 dollars) and margin percentage by year, with two panels showing small molecule brands and small molecule generics separately in each. Colors on each bar distinguish between supply chain entities – providers and wholesalers. Provider margins are higher than wholesaler margins for both groups. Margin amounts are lower for both on small molecule generics, but providers make higher margin percentages on small molecule generics (over 50% every year compared to below 20% and 40% on small molecule brands). Wholesalers also have higher margin percentages on small molecule generics. See Table B-5 for all data values.

### 4.3.2 Biological Products

All entities retained substantially more, in total dollars, from original biologics than from biosimilars (see Figure 7), largely because there are far more original biologics on the market than biosimilars. Of the net spending on original biologics, manufacturers earned 77.3 percent to 79.6 percent, wholesalers earned 2.5 percent to 3.8 percent, providers earned 16.0 percent to 19.1 percent, and GPOs earned 1.2 percent. Of the net spending on biosimilars, manufacturers earned 62.4 percent to 68.0 percent, wholesalers earned 3.6 percent to 4.4 percent, providers earned 26.5 percent to 32.1 percent, and GPOs earned 1.0 percent to 1.1 percent. As a fraction of their net sales prices, both wholesalers and providers earned higher margin percentages on biosimilars than original biologics. Wholesalers’ margin percentage on original biologics decreased from 2020 to 2022 (see Figure 8).

Figure 7 Distribution to Supply Chain of Payer-Beneficiary Net Spending on Original Biologics and Biosimilars

Note: Some data columns for GPOs may be too small to see at this scale.

Two stacked bar plots show amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year on biologics, with two panels showing original biologics and biosimilars separately in each. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Total net spending is much higher on original biologics than on biosimilars. Manufacturers retain a higher percentage of net spending on original biologics than biosimilars, with the opposite being true for providers. See Table B-6 for all data values.

Figure 8 Providers and Wholesalers’ Margins on Original Biologics and Biosimilars

Note: Manufacturer margins are not estimated because they do not generally pay an acquisition cost for the finished drug product, and we did not quantify their raw ingredient costs. GPO margins are not estimated because they generally do not pay or get paid for the full cost of the drug.

Two grouped bar plots show margins (in billion 2023 dollars) and margin percentage by year on biologics, with two panels showing original biologics and biosimilars separately in each. Colors on each bar distinguish between supply chain entities – providers and wholesalers. Provider margins are higher than wholesaler margins for both groups. Margin amounts are lower for both on biosimilars, but providers make higher margin percentages on biosimilars (over 20% every year compared to below 20% on original biologics). Wholesalers also have higher margin percentages on biosimilars. See Table B-7 for all data values.

## 4.4 Noncompetitive vs. Competitive Drugs or Products

### 4.4.1 Small Molecule Drugs

Among small molecules, total net spending was roughly twice as high on noncompetitive drugs as on competitive drugs (see Figure 9).^38^ Across the three years of the study period, manufacturers’ annual share of net spending was 66.4 percent to 70.6 percent for noncompetitive small molecule drugs but only 36.9 percent to 49.1 percent for competitive small molecule drugs—though the latter rose steadily from 2020 to 2022. Providers’ annual share of net spending across the three years ranged from 48.1 percent to 58.6 percent for competitive small molecule drugs, compared to just 26.2 percent to 30.5 percent for noncompetitive small molecule drugs. Wholesalers’ annual share of net spending ranged from 2.1 percent to 2.7 percent for noncompetitive small molecule drugs and 2.0 percent to 5.1 percent for competitive small molecule drugs. GPOs’ annual share of net spending was 0.7 percent to 0.8 percent for competitive small molecule drugs and 1.0 percent for noncompetitive small molecule drug spending. Providers and wholesalers both earned substantially higher margin percentages on competitive drugs than on noncompetitive drugs (see Figure 10).

When expressed in dollars per package^39^, the share of net spending on noncompetitive drugs was much higher than for competitive small molecules for all entities, and across both brands and generics (see Figure 11). Manufacturers, which retain the largest share per package across all small molecule drug types, retained $12 to $26 per package on competitive small molecule generics compared to $82 to $210 per package on noncompetitive small molecule generics (six to eight times as much). For small molecule brands, they retained $288 to $546 per package on competitive drugs and between $801 and $899 per package on noncompetitive drugs. Wholesalers retained four to nine times as much per package on noncompetitive small molecule brand drugs compared to competitive small molecule brands, and two to nine times as much on noncompetitive small molecule generics compared to competitive small molecule generics. For providers, the dollar amount retained per package was one to three times as much on small molecule brands, and three to seven times as much on small molecule generics. GPOs retained one to four times as much on small molecule brands and five to nine times as much on small molecule generics.

Figure 9 Distribution to Supply Chain of Payer-Beneficiary Net Spending on Small Molecule Drugs, Competitive vs. Noncompetitive Markets

Note: Some data columns for GPOs may be too small to see at this scale.

Two stacked bar plots show amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year on small molecules, with two panels showing noncompetitive small molecules and competitive small molecules separately in each. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Total net spending is larger on noncompetitive small molecules than competitive. Providers retain close to 50% of net spending (slightly over or under by year) on competitive small molecules, while manufacturers retain a larger percentage on noncompetitive small molecules. See Table B-9 for all data values.

Figure 10 Providers and Wholesalers’ Margins on Small Molecule Drugs, Competitive vs. Noncompetitive Markets

Note: Manufacturer margins are not estimated because they do not generally pay an acquisition cost for the finished drug product, and we did not quantify their raw ingredient costs. GPO margins are not estimated because they generally do not pay or get paid for the full cost of the drug.

Two grouped bar plots show margins (in billion 2023 dollars) and margin percentage by year on small molecules, with two panels showing noncompetitive small molecules and competitive small molecules separately in each. Colors on each bar distinguish between supply chain entities – providers and wholesalers. Provider margins are higher than wholesaler margins for both groups. Despite lower total net spending on competitive small molecules, providers have similar margins on both groups. Both have higher margin percentages on competitive small molecules. See Table B-9 for all data values.

Figure 11 Distribution to Supply Chain of Payer-Beneficiary Net Spending per Package on Brand and Generic Small Molecule Drugs, Competitive vs. Noncompetitive Markets

Note: Some data columns for GPOs may be too small to see at this scale. The y-axis shows the unweighted sum of retained net expenditures divided by the total number of packages sold, for drugs in the sample with known package size.

A stacked bar plot shows amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year on small molecules, with four panels showing subgroups. Columns show competitive versus noncompetitive drugs and rows show brand small molecules versus generic small molecules. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Total net spending is largest on noncompetitive brand small molecules and lowest on competitive generics. Manufacturers retain the highest amount on brands, both competitive and noncompetitive, but providers are much closer on generics. See Table B-10 for all data values.

### 4.4.2 Biological Products

From 2020 to 2022, net spending on competitive biologics decreased despite growth in the number of competitive biologics and a rising number of those markets—a sign of declining prices. Net spending on noncompetitive biologics increased (see Figure 12).^40^ Over the full study period, noncompetitive biologics accounted for 85.1 percent of all net spending on biologics. As a fraction of net spending, manufacturers retained 77.4 percent to 80.0 percent of net spending on noncompetitive biologics and 68.2 percent to 72.0 percent of net spending on competitive biologics. Wholesalers retained 2.5 percent to 3.9 percent on noncompetitive biologics and roughly the same (3.3 percent to 3.6 percent) on competitive biologics. Providers also retained approximately half again as much of net spending on competitive biologics (23.3 percent to 27.5 percent) as noncompetitive biologics (14.9 percent to 19.0 percent). GPOs retained the same share of net spending on noncompetitive biologics (1.2 percent) as competitive biologics (1.0 percent to 1.2 percent). As with small molecules, both providers and wholesalers earned higher margin percentages on competitive biologics (see Figure 13).

Unlike small molecules, net spending retained per package was higher for all entities on competitive original biologics compared to noncompetitive original biologics (see Figure 14). Many biosimilars are oncology drugs, which have higher spending per package than any other therapeutic area. Additionally, biosimilars are more likely to enter larger biologics markets. For these reasons, competitive biologic markets are not directly comparable to noncompetitive biologics markets, since the former contain higher-value products. All supply chain entities made roughly one to four times more on competitive original biologics than noncompetitive original biologics, when measured in dollars per package.

Figure 12 Distribution to Supply Chain of Payer-Beneficiary Net Spending on Biologics, Competitive vs. Noncompetitive Markets

Note: Some data columns for GPOs may be too small to see at this scale.

Two stacked bar plots show amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year on biologics, with two panels showing noncompetitive biologics and competitive biologics separately in each. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Total net spending is larger on noncompetitive biologics than competitive. Manufacturers retain the largest amount on both competitive and noncompetitive biologics. See Table B-11 for all data values.

Figure 13 Providers and Wholesalers’ Margins on Biologics, Competitive vs. Noncompetitive Markets

Note: Manufacturer margins are not estimated because they do not generally pay an acquisition cost for the finished drug product, and we did not quantify their raw ingredient costs. GPO margins are not estimated because they generally do not pay or get paid for the full cost of the drug.

Two grouped bar plots show margins (in billion 2023 dollars) and margin percentage by year on biologics, with two panels showing noncompetitive biologics and competitive biologics separately in each. Colors on each bar distinguish between supply chain entities – providers and wholesalers. Provider margins are higher than wholesaler margins for both groups. Providers have higher margin percentages on competitive biologics, while wholesaler margin percentages look very similar. See Table B-12 for all data values.

Figure 14 Distribution to Supply Chain of Payer-Beneficiary Net Spending per Package on Original Biologics and Biosimilars, Competitive vs. Noncompetitive Markets

Note: Some data columns for GPOs may be too small to see at this scale. The y-axis shows the unweighted sum of retained net expenditures divided by the total number of packages sold, for drugs in the sample with known package size. The panel for noncompetitive biosimilars is blank because all biosimilars are in competitive biologic markets.

A stacked bar plot shows amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year on biologics, with four panels showing subgroups. Columns show competitive versus noncompetitive drugs and rows show original biologics versus biosimilars. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Total net spending is larger on competitive biologics and biosimilars compared to noncompetitive original biologics. The panel for noncompetitive biosimilar is blank because all biosimilars are competitive. Manufacturers retain the largest amount on all subgroups, but provider share on biosimilars is higher than on noncompetitive or competitive biologics. See Table B-13 for all data values.

## 4.5 340B Discount Status

We also considered net spending on drug units that received 340B discounts, compared to drug units that did not receive 340B discounts.^41^ While net spending on non-340B-discounted drugs was relatively constant, net spending on 340B-discounted drugs rose by 19.9 percent from 2020 ($12.9 billion) to 2022 ($15.5 billion). In 2022, 340B-discounted units accounted for 34.8 percent of net spending on all drugs. Almost all of this growth in 340B net spending was captured by providers, for which 340B-discounted drugs generated more profit (see Figure 15). Compared to non-340B-discounted drugs, providers’ margin percentages on 340B-discounted drugs were higher by 59.2 percent, 80.5 percent, and 165.9 percent in 2020, 2021, and 2022, respectively (see Figure 16). As expected, manufacturers earned lower shares of net spending on 340B-discounted drugs (59.6 percent to 67.3 percent) than on non-340B-discounted drugs (77.5 percent to 81.9 percent). Wholesalers earned higher shares of net spending on 340B-discounted drugs (3.4 percent to 5.1 percent) than non-340B-discounted drugs (2.0 percent to 3.0 percent). This was not unexpected, as we assumed that wholesalers earned the same dollar margin regardless of 340B discount status, and 340B-discounted drugs have lower prices. GPOs earned larger shares of non-340B drug net spending (1.5 percent to 1.6 percent) than 340B drug spending (0.3 percent), as many 340B covered entities are prohibited from participating in GPOs. Providers earned 27.7 percent to 36.7 percent of net spending on 340B-discounted drugs, compared to 14.5 percent to 18.0 percent of net spending on non-340B-discounted drugs.

Figure 15 Distribution to Supply Chain of Payer-Beneficiary Net Spending on All Drugs, by 340B Discount Status

Note: Some data columns for GPOs may be too small to see at this scale.

Two stacked bar plots show amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year, with two panels showing non-340B-discounted drugs and 340B-discounted separately in each. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Total net spending is larger on non-340B-discounted drugs than 340B-discounted, but net spending on 340B-discounted drugs grows between 2020 and 2022. Manufacturers retain the largest amount on both subgroups. See Table B-14 for all data values.

Figure 16 Providers and Wholesalers’ Margins on All Drugs, by 340B Discount Status

Note: Manufacturer margins are not estimated because they do not generally pay an acquisition cost for the finished drug product, and we did not quantify their raw ingredient costs. GPO margins are not estimated because they generally do not pay or get paid for the full cost of the drug.

Two grouped bar plots show margins (in billion 2023 dollars) and margin percentage by year, with two panels showing non-340B-discounted drugs and 340B-discounted separately in each. Colors on each bar distinguish between supply chain entities – providers and wholesalers. Provider margins are higher than wholesaler margins for both groups. Providers have growing margin percentages on 340B-discounted drugs. See Table B-15 for all data values.

## 4.6 Therapeutic Areas

On average, approximately $20.8 billion was spent on oncology drugs per year, which is nearly half (48.1 percent) of total net spending. Each year, oncology drug spending was three to four times as much as net spending on immune modulators, the next highest-spend therapeutic area. As Figure 17 shows, oncology drugs generated ranges of $14.4 billion to $16.1 billion per year for manufacturers (72.4 percent to 74.4 percent of net spending); $529 million to $699 million for wholesalers (2.3 percent to 3.6 percent); $4.2 billion to $5.4 billion for providers (21.3 percent to 24.2 percent); and $194 million to $218 million for GPOs (1.0 percent).

Total net spending on oncology drugs rose by 13.8 percent from 2020 to 2022. Each supply chain entity except wholesalers retained more from oncology drugs in 2022 than in 2020—with providers retaining 26.9 percent more in total dollars, manufacturers and GPOs retaining 11.9 percent and 12.3 percent more, respectively, and wholesalers earning 24.4 percent less. Wholesalers earned almost the exact same margin percentages from oncology as from other therapeutic areas, but providers gained slightly higher margin percentages from oncology drugs (see Figure 18).

Figure 17 Distribution to Supply Chain of Payer-Beneficiary Net Spending on All Drugs, by Therapeutic Area

Note: Some data columns for GPOs may be too small to see at this scale.

Two stacked bar plots show amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year, with three panels showing oncologics, immune modulators, and all other therapeutic areas separately in each. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Total net spending is larger on oncologics than immune modulators and all other therapeutic areas put together. Manufacturers retain the largest amount on all subgroups. See Table B-16 for all data values.

Figure 18 Providers and Wholesalers’ Margins on All Drugs, by Therapeutic Area

Note: Manufacturer margins are not estimated because they do not generally pay an acquisition cost for the finished drug product, and we did not quantify their raw ingredient costs. GPO margins are not estimated because they generally do not pay or get paid for the full cost of the drug.

Two grouped bar plots show margins (in billion 2023 dollars) and margin percentage by year, with three panels showing oncologics, immune modulators, and all other therapeutic areas separately in each. Colors on each bar distinguish between supply chain entities – providers and wholesalers. Provider margins are higher than wholesaler margins for both groups. See Table B-17 for all data values.

## 4.7 Acute and Chronic Conditions

Acute conditions, which include most forms of cancer, made up roughly three-quarters of net spending (74.5 percent across all years). Each supply chain entity generally retained about the same share of net spending on acute condition drugs as they did on chronic condition drugs, as Figure 19 shows. Wholesalers and providers, though, had slightly higher margin percentages on drugs treating acute conditions, which also generated more margin dollars (see Figure 20).

Figure 19 Distribution to Supply Chain of Payer-Beneficiary Net Spending on All Drugs, by Acute vs. Chronic Condition

Note: Some data columns for GPOs may be too small to see at this scale.

Two stacked bar plots show amount of net spending retained (in billion 2023 dollars) and percentage of net spending retained by year, with two panels showing drugs used to treat acute and chronic conditions separately in each. Colors on each stacked bar indicate the supply chain entity from providers, GPOs, wholesalers, and manufacturers. Total net spending is larger on drugs used to treat acute conditions than those used to treat chronic conditions. Manufacturers retain the largest amount on both subgroups. See Table B-18 for all data values.

Figure 20 Providers and Wholesalers’ Margins on All Drugs, by Acute vs. Chronic Condition

Note: Manufacturer margins are not estimated because they do not generally pay an acquisition cost for the finished drug product, and we did not quantify their raw ingredient costs. GPO margins are not estimated because they generally do not pay or get paid for the full cost of the drug.

Two grouped bar plots show margins (in billion 2023 dollars) and margin percentage by year, with two panels showing drugs used to treat acute and chronic conditions separately in each. Colors on each bar distinguish between supply chain entities – providers and wholesalers. Provider margins are higher than wholesaler margins for both groups. See Table B-19 for all data values.

## 4.8 Empirical Confidence Intervals

Table 3 presents the Monte Carlo uncertainty analysis results. Each point estimate in Table 3 is the average from the 10,000 bootstrap samples, and the values in parentheses are 95 percent confidence intervals. The point estimates from the Monte Carlo simulation are generally similar to the main estimates presented above (see also Table B-2 and Table B-3), indicating that the simulation had low bootstrapping bias. For estimates involving payer and beneficiary net spending, however, the bootstrapped means are consistently less than main estimates presented above (generally by no more than 16 percent of the original estimate). This occurred because, when resampling the original dataset, there was a tendency for strata with fewer observations to be omitted entirely. Consequently, these missing strata were not represented in the weighted estimates of total net spending by the payer and beneficiary, causing a slight systematic reduction in the amount of net spending captured by each supply chain entity. The mean estimates for percentage of net spending retained and margin percentage, however, were highly similar in the Monte Carlo analysis to the point estimates from the main analysis and appear to give unbiased estimates of the confidence intervals.

The confidence intervals are relatively narrow. For estimates involving net spending, the 95 percent confidence intervals are all less than ±$6.3 billion in width or ±23.8 percent of the bootstrap mean. For estimates of the percentage of payer and beneficiary spending retained, the 95 percent confidence intervals are all less than ±4.4 percentage points, or 31.8 percent of the bootstrap mean. For estimates of margin percentages, the 95 percent confidence intervals are all less than 3.9 percentage points or 33.6 percent of the bootstrap mean.

Table 3 Monte Carlo Results: Mean Annual Net Spending Distributed to Supply Chain Participants and Margins on All Drugs, 2020–2022

Year | Entity | Mean Net Spending Retained (95% CI) (Billions, 2023 $) | Percentage of All Net Spending Retained (95% CI) | Margin Percentage ^[a]^ (95% CI)
2020 | Manufacturer | $26.63 ($23.06 – $28.79) | 74.71% (72.23% – 76.62%) | Not estimated
2020 | Wholesaler | $1.38 ($1.24 – $1.51) | 3.88% (3.45% – 4.54%) | 4.76% (4.24% – 5.60%)
2020 | GPO | $0.40 ($0.34 – $0.44) | 1.13% (1.06% – 1.20%) | Not estimated
2020 | Provider | $7.22 ($6.35 – $7.99) | 20.28% (18.35% – 22.44%) | 19.70% (17.84% – 21.76%)
2021 | Manufacturer | $27.77 ($23.95 – $30.09) | 75.70% (73.49% – 77.11%) | Not estimated
2021 | Wholesaler | $1.29 ($1.14 – $1.42) | 3.53% (3.06% – 4.18%) | 4.27% (3.73% – 5.07%)
2021 | GPO | $0.43 ($0.36 – $0.46) | 1.16% (1.09% – 1.23%) | Not estimated
2021 | Provider | $7.19 ($6.38 – $7.97) | 19.61% (18.14% – 21.63%) | 18.94% (17.50% – 20.87%)
2022 | Manufacturer | $27.93 ($24.03 – $30.28) | 73.91% (71.43% – 75.47%) | Not estimated
2022 | Wholesaler | $1.04 ($0.93 – $1.14) | 2.77% (2.42% – 3.31%) | 3.45% (3.01% – 4.17%)
2022 | GPO | $0.42 ($0.36 – $0.46) | 1.12% (1.05% – 1.21%) | Not estimated
2022 | Provider | $8.38 ($7.40 – $9.12) | 22.19% (20.60% – 24.36%) | 21.41% (19.87% – 23.44%)

Note: Point estimate is the mean across the 10,000 bootstrap samples. Values in parentheses are empirical 95 percent confidence intervals (CIs). For estimates of the amount of net spending retained, the bootstrapped means are consistently below the point estimates from the main results (see Table B-2 and Table B-3).

[a] The total dollar margin is equal to the amount of net spending retained (billion 2023 $).

35 The sum of competitive and noncompetitive drugs is more than the total number of drugs because, during the study period, some drugs changed from having a competitive status to a noncompetitive status (or vice versa).

36 All dollar amounts are adjusted to 2023 dollars.

37 As stated previously, margins were not estimated for manufacturers because their acquisition costs are not known and do not represent the purchase of a finished drug product. GPO margins are not estimated because they are not paid and do not make payments for the full cost of the drug.

38 For small molecules, we defined single-source drugs (as listed by CMS) as noncompetitive and multi-source drugs as competitive.

39 See explanation of “per package” conversion at the end of section 3.3.1. Analysis of net spending per package is unweighted (i.e., does not scale up to the study population) and is limited to those drugs in the sample with known package sizes.

40 We defined competitive biologics to include reference products and all of their marketed biosimilars.

41 Unlike most other comparisons in the Results section, 340B discount status is not uniquely associated with specific drug products. A single drug product would have some 340B-discounted sales and some non-340B-discounted sales if administered at both 340B facilities and non-340B facilities. Our methods accounted for this by estimating separate prices and volumes of drug sold for units administered to Medicare Part B beneficiaries at 340B facilities versus at non-340B facilities. As stated previously, drugs administered to Medicaid beneficiaries do not receive 340B discounts.