# 3 METHODOLOGY

## 3.1 Data Sources

To answer the research questions, we used the following public and proprietary data sources. For each source listed below, we used full year data for 2020, 2021, and 2022.

■ IQVIA National Sales Perspective (NSP). The NSP dataset is a nationally representative database covering over 90 percent of all U.S. drug sales. Sales data are reported monthly by distribution channels (e.g., chain pharmacy, clinic, non-federal hospital, etc.). Metrics include each drug’s brand status (brand, generic, branded generic), market launch date, molecule type (small molecule, original biologic, biosimilar)^15^, dosage form, therapeutic class, and sales information. We used the WAC published by manufacturers, which does not contain any discounts, and the NSP price, which is IQVIA’s estimate of the average price listed on the invoice to clinics, which accounts for on-invoice discounts but does not capture off-invoice discounts. We also used the number of extended units sold—an “extended unit” in IQVIA represents the smallest measurable quantity of a drug as sold (e.g., one tablet or capsule, one mL of solution, one vial, one tube of ointment). These data helped us estimate providers’ net acquisition costs.
■ Centers for Medicare & Medicaid Services (CMS) Part B Fee-for-Service (FFS) Outpatient Claims File. The Part B FFS Outpatient file contains NDC-level data on pharmaceutical claims from outpatient settings for Medicare Part B beneficiaries (ResDAC, 2020-2022). These data include the total amounts paid by Medicare, the beneficiary, and other payers (e.g., supplemental insurance) to the provider. The FFS Outpatient file also lists the amount of drug administered, the drug product’s 11-digit NDC, and the drug product’s Healthcare Common Procedure Coding System (HCPCS) code. We used these data to estimate total Part B outpatient drug spending as well as reimbursement rates for specific outpatient drugs.
■ CMS Medicare Part B FFS Carrier Claims File. The Part B FFS Carrier file contains data on pharmaceutical claims from physician offices for Medicare Part B beneficiaries (ResDAC, 2024). The data include the total payment amount, the amount of drug administered, and the drug product’s HCPCS code. We used these data to estimate total Part B physician office drug spending by HCPCS and the provider’s 340B status. Drug-level prices were not available in this file.
■ CMS Medicaid Other Services (OT) Claims Files. The Medicaid OT file contains data on pharmaceutical claims from outpatient facilities and physician offices for Medicaid beneficiaries (ResDAC, 2020-2022). This includes the total payment amount, along with the drug’s HCPCS code and 11-digit NDC. We used these data to estimate total Medicaid drug spending in outpatient settings and physician offices.
■ CMS Part B HCPCS-NDC Crosswalks. Quarterly, CMS posts a crosswalk of 11-digit NDCs and their corresponding HCPCS information (Centers for Medicare & Medicaid Services, 2020-2022). The list of 11-digit NDCs covers all drugs for which CMS has calculated and published a Part B reimbursement rate.^16^ The crosswalk files list each drug’s corresponding HCPCS code, standardized dosage per billing unit, and total number of billing units (i.e., dosages) per 11-digit NDC shelf package. We used the HCPCS in these crosswalks to identify the universe of spending on Part B drugs. We also used dosage and package information in the crosswalks to convert prices and utilization to consistent units within and across datasets.^17^
■ CMS Medicaid Drug Rebate Program Drug (MDRP) Product Data. CMS publishes a list of 11-digit NDCs in the MDRP (Medicaid.gov, 2020-2022). Each product is identified as (1) a single-source drug, a non-innovator multi-source drug, or an innovator multi-source drug; and (2) a clotting factor or exclusively pediatric drug. We used this dataset when calculating Medicaid rebates and 340B prices.
■ U.S. Department of Veterans Affairs Federal Supply Schedule (FSS) Drug Pricing File. The VA FSS drug pricing files provide data on maximum prices that drug manufacturers may charge for direct federal purchases made by the Department of Veterans Affairs, the Department of Defense, the Public Health Service, and the Coast Guard (U.S. Department of Veterans Affairs, Office of Procurement, Acquisition and Logistics, 2023).^18^ We used the VA FSS prices to estimate wholesalers’ net acquisition costs, as described in more detail in section 3.3.
■ U.S. Food & Drug Administration (FDA) NDC Directory. The NDC Directory contains information about finished drugs marketed in the United States, as provided to FDA in mandatory biannual submissions from registered drug manufacturing establishments. This information includes the first two segments of the drug’s NDC number, application number and type, prescription status, dosage form, and strength. Where needed, we converted the NDC numbers listed in the NDC Directory to the standardized 9-digit format used by CMS for billing (Maryland Department of Health, n.d.). We used these data to identify products’ strength, application type (New Drug Application, Abbreviated New Drug Application, or Biologics License Application), and brand or generic status in cases where the drug was listed in IQVIA as “branded generics” or “other.”

## 3.2 Universe and Sample of Drug Spending

Our study covered drugs administered by healthcare professionals to Medicare Part B and Medicaid beneficiaries in outpatient or physician office settings (excluding Medicare Advantage).^19^ We limited the study to HCPCS codes listed in the CMS Part B HCPCS-NDC Crosswalk files (Centers for Medicare & Medicaid Services, 2020-2022) and only considered separately payable drug claims that were not bundled with other medical services. For more information on the inclusion criteria, see APPENDIX A.

To define the size of the universe and the sample, we used gross spending by the payer(s) and beneficiary, which we estimated using the claims data. Figure 1 shows that the full target population represented $129.9 billion in gross spending on Medicare Part B beneficiaries across all three years of the study period (2020 to 2022) and $27.5 billion in gross spending on Medicaid beneficiaries. We also defined a slightly narrower study population that excluded drug groups or strata^20^ with no data in the sample. The study population included 87.7 percent of in-scope Medicare Part B drug spending ($113.9 billion) and 72.5 percent of in-scope Medicaid drug spending ($19.9 billion).

Sample selection was based on data availability, which led to a final sample that covered 29.3 percent ($33.4 billion) of spending by the Medicare Part B study population and 26.8 percent ($5.4 billion) of spending by the Medicaid study population. The Medicare Part B sample data drew exclusively from outpatient settings because NDCs are only available in the Medicare Part B FFS Outpatient file and are unavailable in the Medicare Part B FFS Carrier file. We were, however, able to use strata-level spending totals in the Carrier file when calculating weights, such that the weighted results cover both outpatient and physician office spending on Medicare Part B beneficiaries. This approach requires an assumption that, in Medicare Part B, outpatient reimbursement rates are the same as physician reimbursement rates. This is a reasonable assumption because all payments in Medicare Part B are primarily based on published CMS ASP files (Centers for Medicare & Medicaid Services, 2020-2022).

When selecting data for the sample, not all failed matches were due to omissions in IQVIA NSP. NDCs in the claims data may have contained typographical errors, outdated codes, or other product codes besides the FDA-issued NDC. Moreover, we relied on the published CMS NDC-HCPCS Crosswalk files to identify the relevant NDCs to analyze in IQVIA NSP. Some of the drugs that were dropped from the sample thus may have been missing in IQVIA NSP, while others likely had invalid NDCs or were not in our IQVIA NSP dataset because they were not listed in the CMS NDC-HCPCS Crosswalk file. HCPCS codes starting with Q (temporary codes), C (new, unclassified, or miscellaneous drugs), and J (non-oral and chemotherapy drugs) had more coverage, with the sample containing 65.8, 67.5, and 71.2 percent, respectively, of the study population of gross spending on those drugs. HCPCS codes starting with A (ambulatory services), P (pathology and lab services), or 9 (vaccines) had less coverage, with the sample containing 25.5, 29.0, and 39.4 percent, respectively, of the study population of gross spending on those drugs. While these limitations reduced the sample size, the results reported in section 4 use weights to scale up the estimates from the sample to the study population.

Figure 1 Reimbursements and Payments to Target Population, Study Population, and Sample, 2020–2022

Note: All monetary values expressed in 2023 dollars. All spending estimates represent gross spending by payers and beneficiaries during the full study period from 2020 through 2022. Of the strata excluded from the study population due to lack of data, most drugs are classified as miscellaneous or vaccines.

[a] Medicaid values include spending at both outpatient settings and physician offices.

[b] We did not have drug-level data for this setting because the Medicare Part B FFS Carrier file does not have 9-digit NDCs. Some NDCs in the claims data that did not match to IQVIA NSP may have had typographical errors.

A Venn diagram with three concentric circles. The largest, the target population, includes all drugs reimbursed by Part B Fee For-Service (FFS) plans in Medicare and the same drugs for Medicaid, limited to outpatient setting or physician office. The target population shows spending of $58.6 billion in Part B outpatient, $71.3 billion in Part B physician, and $27.5 billion in Medicaid. The next smaller circle, the study population contains $53.2 billion, $60.7 billion, and $19.9 billion of spending in Part B outpatient, Part B physician, and Medicaid respectively. The study population excludes strata with no drugs in the sample, which comprise 12.3% and 27.6% of Part B and Medicaid spending, respectively. The smallest circle, the sample, comprises $33.4 billion, $0B, and $5.4 billion of spending in Part B outpatient, Part B physician. The sample excludes observations with no drug-level data in IQVIA NSP or claims, and outliers – this excludes 70.7% and 72.9% of Part B and Medicaid spending, respectively.

## 3.3 Analytic Framework

### 3.3.1 Modeled Payment Flows and Supply Chain Intermediaries

Our stylized model of payment and drug flows is shown in Figure 2. Flows of payment are indicated by lowercase letters and solid lines; flows of drug product are indicated by uppercase letters and dotted lines. In this stylized model, the supply chain members form a closed system, with money entering when the payer and the beneficiary pay for the drug product.^21^ All of this monetary input then gets distributed among the various supply chain members. We similarly assumed that the quantity of drug being sold is conserved at each stage of the supply chain, such that every unit of drug acquired by the wholesaler is sold to a provider, etc. The distinction between gross spending and net spending is relevant for Medicaid claims, because gross spending by Medicaid is offset by rebates that manufacturers pay to the federal government and state agencies.

Figure 2 Modeled Payment and Drug Flows

[a] To avoid underestimating margins, we summed all payments by the public payer, the beneficiary, and any other payers (e.g., supplemental insurance). [b] The GPO payment 4a is only triggered by drug flows 2B and 2C; prohibited 340B facilities are not permitted to participate in GPOs and include disproportionate share hospitals, children’s hospitals, and free-standing cancer hospitals. Contractually, the GPO serves as an intermediary between the provider and the wholesaler or manufacturer. This is not reflected in the figure because payments to (or by) the GPO are not for the full cost of the drug.

Two flowcharts show the stylized model of flows of payments and drug units through the supply chain, for Medicare Part B and Medicaid claims respectively. The Medicare Part B flow shows drug units flowing from the manufacturer to the wholesaler to providers (including prohibited 340B facilities, non-prohibited 340B facilities, and non-340B facilities) to the payer (Medicare Part B and the beneficiary). Payments flow the opposite way. Colors distinguish between 340B drug units and payments (which go through prohibited and non-prohibited 340B facilities) and non-340B, which go through non-340B facilities. Two additional payment flows are shown to GPOs (group purchasing organizations) - one from non-prohibited 340B facilities and non-340B facilities, and the other from the wholesaler. The Medicaid flow of drug units goes from the manufacturer to the wholesaler to the provider (outpatient facility/physician office) to the payer (Medicaid and the beneficiary, and payments flow the other way. An additional flow of payment is shown from the wholesaler to the GPO.

Table 1 Definitions and Estimation Methods for Payment Flows ^[a]^

Flow | Description | Estimation Method
Medicare Part B
1a, 1b, 1c | Provider’s net sales price for Medicare beneficiary. | Calculated from Medicare FFS Outpatient claims data.
2a | Provider’s net acquisition cost on 340B-discounted drugs, and wholesaler’s net sales price. | Calculated as 3a + (2c – 3b) based on the assumption that 340B-discounted drugs generate the same margin to wholesalers as non-340B-discounted drugs.
2b | Provider’s net acquisition cost on 340B-discounted drugs, and wholesaler’s gross sales price. | Equal to flow 2a.
2c | Provider’s net acquisition cost on non-340B-discounted drugs, and wholesaler’s gross sales price. | Calculated as the average IQVIA NSP price to clinics.
Not shown | Wholesaler’s net sales price on drug flows 2B and 2C. | Calculated as 2b – 4a and 2c – 4a, respectively.
3a | Wholesaler’s net acquisition cost on 340B-discounted drugs. | Calculated as (i) 13% × 3b, for most generics; (ii) the minimum of 17.1% × 3b or the lowest NSP invoice price to any sales channel, for blood clotting factors and pediatric drugs; and (iii) the minimum of 23.1% × 3b or the lowest NSP invoice price to any sales channel, for most brand drugs.
3b | Wholesaler’s net acquisition cost on non-340B-discounted drugs. | Calculated as either the average or predicted VA FSS price.
4a, 4c | GPO’s administrative fee on flow 2B or 2C (flow 2A generates no GPO fee). | Calculated as 1.7175% × 2b or 1.7175% × 2c, respectively.
4b | Membership fees, which some GPOs assess to healthcare providers. | Not estimated (assumed to be zero).
Medicaid
1d | Provider’s gross sales price for Medicaid beneficiary. | Assumed to equal flow 1c.
2d | Provider’s net acquisition cost and wholesaler’s gross sales price. | Equal to flow 2c.
3c | Wholesaler’s net acquisition cost on non-340B-discounted drugs. | Equal to flow 3b.
4a | GPO’s administrative fee on flow 2D. | Calculated as 1.7175% × 2d.
5a | Medicaid rebate | Calculated as 3b – 3a based on the assumption that the Medicaid unit rebate amount is equal to the 340B-discounted unit rebate amount.
Not shown | Net spending | Calculated as 1d – 5a.

[a] Drug quantities (flows 1A, 1B, 1C, and 1D) were estimated using Medicare and Medicaid claims data. Other drug product flows conserve the total amount in the system, such that (i) 1A = 2A, (ii) 1B = 2B, (iii) 1C = 2C = 3B, (iv) 1D = 2D = 3C, and (v) 3A = 2A + 2B.

Flows 1a, 1b, 1c, and 1d show the payment by the payer(s) and beneficiary to the provider, representing the provider’s sales price. For Medicare beneficiaries, we estimated the provider’s sales prices (1a, 1b, and 1c) and the quantity of drug sold (1A, 1B, and 1C) using the sample of Medicare Part B FFS claims data. In the case of Medicare Part B, drug-level spending and utilization (i.e., drug quantity administered) were available for outpatient claims but not physician office claims. We therefore assumed that physician offices were reimbursed at the same rates as outpatient facilities (Centers for Medicare & Medicaid Services, 2020-2022).^22,23^ For Medicaid reimbursements (flows 1d and 1D), drug-level spending was available for both outpatient and physician offices, but the quantity of drug administered was not. Thus, we assumed that the prices reimbursed by Medicaid were equal to those reimbursed by Medicare Part B.^24^ To estimate the quantity of drug sold to Medicaid beneficiaries, we divided the total payments by the observed Medicare Part B outpatient price.^25^ To avoid underestimating providers’ sales prices, we calculated total payment as the sum of all payments made by the public payer, the beneficiary, and any other payer(s). In the case of Medicare payments (flows 1a, 1b, and 1c), we considered three types of providers: disproportionate share 340B facilities, which are prohibited from participating in a GPO (“prohibited 340B facility”); non-disproportionate share 340B facilities, which are permitted to participate in GPOs (“non-prohibited 340B facility”); and non-340B facilities.^26^ For the Medicaid reimbursements (flows 1d and 1D), we did not distinguish on the basis of 340B status because providers are not eligible to receive 340B discounts when acquiring drugs administered to Medicaid beneficiaries. Thus, in this study, references to “340B-discounted drugs” only refer to the specific units of the drug sold to the provider at 340B-discounted prices. A single drug generally will have some 340B-discounted sales and some non-340B-discounted sales, and our analysis accounts for this.

Flows 2a, 2b, 2c, and 2d represent the provider’s acquisition cost and the wholesaler’s sales price. Flows 2a and 2b show 340B-discounted drug sales paid by the wholesaler to the provider. Flows 2c and 2d are for non-discounted drug sales on units that are not eligible for 340B discounted pricing. Non-340B facilities generally pay a higher price to acquire drugs that are administered to Medicare beneficiaries (flow 2c), as do all facilities when purchasing drugs that are administered to Medicaid beneficiaries (flow 2d). We estimated the provider acquisition cost of non-340B-discounted drugs (flows 2c and 2d) as the average IQVIA NSP invoice price paid by clinics.^27^ For the provider’s acquisition cost of 340B-discounted drugs (flows 2a and 2b), we used the estimated 340B-discounted wholesaler acquisition cost (flow 3a, discussed below) and added the usual wholesaler margin on non-340B-discounted units:

( flow 2 a in $ ) = ( flow 2 b in $ ) = ( flow 3 a in $ ) + ( ( flow 2 c in $ ) − ( flow 3 b in $ ) ) Equation 1: Flow 2a in dollars equals Flow 2b in dollars, which equals Flow 3a in dollars plus Flow 2c in dollars minus Flow 3b in dollars. (1)

Because we modeled the supply chain as a closed system, the quantity of drug sold to the provider (flows 2A, 2B, 2C, and 2D) is equal to the quantity sold to the payer and beneficiary (flows 1A, 1B, 1C, and 1D, respectively).

Flows 3a, 3b, and 3c show the wholesaler’s net acquisition cost, which equals the manufacturer’s sales price. The wholesaler’s net acquisition cost is distinct from the WAC (i.e., the list price) that manufacturers publish, which is often higher than the price wholesalers actually pay. We estimated the non-340B-discounted manufacturer sales price (flows 3b and 3c) using the VA FSS pricing data. VA prices reflect actual discounts that manufacturers give to direct purchasers, making them appropriate for estimating the actual net acquisition costs of wholesalers, which also make discounted purchases from manufacturers. Because only some of the drugs in our sample had VA FSS prices, we developed a linear model to predict the average markup between the wholesaler’s net acquisition cost and the wholesaler’s net sales price and used this model to estimate non-340B-discounted manufacturer sales prices. This model accounted for the drug’s status as brand or generic, the year, the drug’s IQVIA NSP invoice price, and the drug’s WAC price. See Appendix A.4 for full details. For the non-340B-discounted flows, the quantities of drug sold to the wholesaler (flows 3B and 3C) are equal to the quantities sold to the provider (flows 2C and 2D, respectively).

To estimate the wholesaler’s net acquisition cost of 340B-discounted drugs (flow 3a), we applied the minimum statutory 340B discount rate to our estimate of the manufacturer’s sales price on non-340B-discounted units (flow 3b), which approximates the AMP (see equation 2).^28^ For brand drugs, we also considered the lowest available IQVIA NSP price to any distribution channel in a given year, and we used this price if it yielded a larger 340B discount than the statutory discount rate.^29^ We did not estimate the inflation component of 340B drug pricing due to lack of data. We used CMS data on the MDRP to identify each sampled drug’s discount as 13 percent, 17.1 percent, or 23.1 percent (Dolan, 2019).

( flow 3 a ) = {( flow 3 b ) min { ( flow 3 b ) min { ( flow 3 b ) ⋅ ⋅ ⋅ ( 1 − 0.13 ) , ( 1 − 0.231 ) , best NSP price } , ( 1 − 0.171 ) , best NSP price } , not applicable if generic if brand if blood factor/pediatric if vaccine Equation 2: Flow 3a equals Flow 3b multiplied by 1 minus 0.13, if generic; minimum of Flow 3b multiplied by 1 minus 0.231, best NSP price, if brand; minimum of Flow 3b multiplied by 1 minus 0.171, best NSP price, if blood factor/pediatric; not applicable if vaccine. (2)

We capped all wholesaler net acquisition costs at the listed WAC, both for 340B-discounted units and non-340B-discounted units. This led to a slight reduction in the estimate of the net wholesaler acquisition cost for less than one percent of observations.

The quantity of a 340B-discounted drug sold to the wholesaler (flow 3A) is equal to the sum of flows 2A and 2B. The quantities of non-340B-discounted drugs sold to the wholesaler (flows 3B and 3C) are equal to the quantities sold to the provider (flows 2C and 2D, respectively).

GPOs negotiate lower prices with suppliers on behalf of healthcare providers and receive an administrative fee per drug unit sold, which is typically paid by the supplier (Cardinal Health Specialty Solutions, 2020; Oakley, 2022; Mulcahy & Kareddy, 2021). Contractually, GPOs are positioned between the provider and the wholesaler (or manufacturer). Figure 2 does not represent GPOs in this manner, however, because payments to or by the GPO do not typically cover the full cost of the drug. For this reason, GPOs are shown to the side, with flows 4a and 4c representing only the GPO administrative fee that is assessed per drug and which we assume is paid by the wholesaler.^30^ We estimated these payments to GPOs (flows 4a, 4c) at 1.7175 percent of the provider’s acquisition cost. This estimate is based on a report by the U.S. Government Accountability Office (GAO) stating that GPOs retain 1.22 to 2.25 percent of the provider’s purchase price (U.S. Government Accountability Office, 2010) and a report on GPOs that the average administrative fee is 1.7 percent (Scott, et al., 2014).^31^ This cost reduces wholesalers’ net sales price by a small amount in our stylized model.

Transactions with GPOs do not represent a sale or acquisition of a drug as there is no flow of the drug product, and payments 4a and 4c do not represent the full cost of the drug to any entity. For these reasons, we did not estimate GPOs’ margins and only estimated the dollar amounts they retained, out of the total spending by the payer and beneficiary. We assumed GPOs were paid administrative fees on all Medicare drugs sold to non-340B and nonprohibited 340B facilities, and also on all Medicaid drugs. In addition to these administrative fees that suppliers pay to GPOs on a volume basis, some GPOs also require healthcare providers to pay an annual membership fee (flow 4b). We did not estimate these membership fees because they are not typically applied on a per-drug basis, and they are not imposed by all GPOs.

The Medicaid drug rebate (flow 5a) was estimated using the same methodology as the 340B price discount, such that 5a was equal to the difference between the non-340B price (flow 3b) and the 340B price (flow 3a):

( 5 a ) = ( 3 b ) − ( 3 a ) Equation 3: 5a equals 3b minus 3a. (3)

Prices and drug quantities were expressed in different units in different datasets (e.g., per package, per HCPCS dosage, per mg of API, per vial). There were also inconsistencies in the units of measurement within a single dataset. Therefore, for each drug in the sample, we selected a single harmonized unit of measurement and converted all prices in all datasets to that unit.^32^ All monetary values were adjusted to 2023 dollars using the medical care consumer price index (CPI) for all urban consumers (U.S. Bureau of Labor Statistics, 2024).

### 3.3.2 Sample Weights

To estimate the margins and spending presented in section 4, we applied weights to our sample data that scale up from the sample to the study population. To compute the weights w_jc_, we compared total payer and beneficiary spending in the sample s to the total spending in the study population S. These calculations were stratified by unique combinations of (a) HCPCS code j and (b) year, payer, provider type, and 340B discount status, collectively indexed by c. The weights were assigned to all sampled NDCs i in the stratum jc. By definition, the weighted sum of spending in the sample w_jc_ · S_ijc_ on all NDCs i in a given stratum jc yields the total spending S_jc_ for that stratum jc in the full study population:

∑_i_ s_i j c_ ⋅ w_j c_ = S_j c_ Equation 4: The summation of s subscript i times j times c multiplied by w subscript j times c over all i equals S subscript j times c. (4)

w_j c_ = (S_j c_)/(∑_i_ s_i j c_) = (S_j c_)/(S_j c_) , where s_j c_ ≡ ∑_i_ s_i j c_ Equation 5: w subscript j times c equals S subscript j times c divided by the summation of s subscript i times j times c over all i, which equals S subscript j times c divided by s subscript j times c, where s subscript j times c is defined as the summation of s subscript i times j times c over all i. (5)

Two sets of weights were developed—one for Medicare Part B drug spending and another for Medicaid drug spending. For the Medicare Part B spending, we only had drug-level data for the outpatient settings, and the weights scale up from the Medicare Part B outpatient sample to the total Medicare Part B drug spending in both outpatient settings and physician offices.

### 3.3.3 Definition of Retained Share of Net Spending and Margins

Gross spending refers to payments by the payer(s) and beneficiary for a drug or group of drugs. Net spending is the total gross spending minus the Medicaid drug rebate (flow 5a). For a given drug i, each supply chain member x= {provider, wholesaler, GPO, manufacturer} retains some amount E_ix_ of the payer and beneficiary’s net spending Σ_x_ E_ix_ to cover their costs and profits. We calculated the retained amount of net spending as the difference between (a) all drug-level payments made to the entity x (i.e., all inflows) for the drug i and (b) all drug-level payments made by the entity x (i.e., all outflows) for the drug i. Dividing by the total spending yields the share %E that entity x retains of the total payer and beneficiary spending Σ_x_ E_ix_.

E_i x_ = ( payment inflows )_i x_ − ( payment outflows )_i x_ Equation 6: E subscript i times x equals payment inflows subscript i times x minus payment outflows subscript i times x. (6)

% E_i x_ = (E_i x_)/(∑_x_ E_i x_) Equation 7: E subscript i times x equals E subscript i times x divided by the summation of E subscript i times x over all x. (7)

For a group of drugs i ∈ I, the amount and percentage of payer and beneficiary net spending retained by supply chain entity x was calculated using weighted sums:

E_I x_ = ∑_i ∈ I_ ( payment inflows )_i x_ ⋅ w_i_ − ( payment outflows )_i x_ ⋅ w_i_ Equation 8: E subscript I times x equals the summation over all i in I of payment inflows subscript i times x multiplied by w subscript i minus payment outflows subscript i times x multiplied by w subscript i. (8)

% E_i x_ = (∑_i ∈ I_ E_i x_ ⋅ w_i_)/(∑_x_ ∑_i ∈ I_ E_i x_ ⋅ w_i_) Equation 9: E subscript I times x equals the summation over all i in I of E subscript i times x multiplied by w subscript i, divided by the summation over all x of the summation over all i in I of E subscript i times x multiplied by w subscript i. (9)

In this report, “margin” refers to the difference between the net sales price s and net acquisition cost a for a given intermediary x = {provider, wholesaler} and a drug i. We used net prices to account for discounts between the selling entity and buying entity. Margins were computed both in dollar terms M and as a percentage of the net sales price %M. The formulas below show the unweighted calculation of the margin and margin percentage for a number of units u that were sold.

M_i x_ = (s_i x_ − a_i x_) u_i_ Equation 10: M subscript i times x equals s subscript i times x minus a subscript i times x, all multiplied by u subscript i. (10)

% M_i x_ = ((s_i x_ − a_i x_) u_i_)/(s_i x_ u_i_) Equation 11: M subscript i times x equals s subscript i times x minus a subscript i times x, all multiplied by u subscript i, divided by s subscript i times x multiplied by u subscript i. (11)

To calculate weighted population estimates of the margins or margin percentages for an entity x across all drugs i in a given group I, we summed the weighted total margin dollars and the weighted total net sales dollars:

M_l x_ = ∑_i ∈ I_ (s_i x_ − a_i x_) u_i_ w_i_ Equation 12: M subscript I times x equals the summation over all i in I of s subscript i times x minus a subscript i times x, all multiplied by u subscript i and w subscript i. (12)

% M_I x_ = (∑_i ∈ I_ ( S_i x_ − a_i x_ ) u_i_ w_i_)/(∑_i ∈ I_ S_i x_ u_i_ w_i_) Equation 13: M subscript I times x equals the summation over all i in I of s subscript i times x minus a subscript i times x, all multiplied by u subscript i and w subscript i, divided by the summation over all i in I of s subscript i times x multiplied by u subscript i and w subscript i. (13)

### 3.3.4 Drug Groups

When analyzing results, we considered spending and margins on all drugs, but we also considered various subgroups of drugs, including:

■ Generic small molecule drugs versus branded small molecule drugs,
■ Biosimilars versus original biologics,
■ Competitive versus noncompetitive drugs,
■ 340B-discounted drugs versus non-340B-discounted drugs,^33^
■ Oncology drugs versus other therapeutic areas, and
■ Drugs treating acute conditions versus chronic conditions.

For small molecules, we assigned each drug’s brand-generic status as reported in IQVIA. For biologics, we used the FDA Purple Book to determine whether each product was an original biologic approved through the 351(a) pathway or a biosimilar approved through the 351(k) pathway (U.S. Food & Drug Administration, 2024). We also used the Purple Book to identify each biosimilar’s reference product, i.e., the original biological product licensed under section 351(a) against which a proposed biosimilar product is evaluated.

For small molecules, we identified competitive and noncompetitive drugs using the multi-source and single-source designations from CMS, respectively (Medicaid.gov, 2020-2022). If a drug changed status in a given year, we assigned the most frequent designation in the sample data. For biologics, we defined competitive products to include any marketed biosimilar and its 351(a) reference biological product. Noncompetitive biologics included any original biological product that did not have competition from one or more marketed biosimilars. We identified the year when biosimilar competition began (Cardinal Health, 2024), and if the first biosimilar entered the market in July or later, we assigned the next calendar year as the first year of biosimilar competition, in order to characterize the competitive status that existed for the majority of the calendar year.

For Medicare spending, we classified each facility on the claim as being a non-340B facility, a disproportionate share 340B facility, or a nondisproportionate share 340B facility. To identify facilities’ 340B status, we matched the Medicare provider number or National Provider ID on the claim to the Office of Pharmacy Affairs 340B covered entities list (Health Resources & Services Administration, 2024). As stated previously, disproportionate share 340B facilities are prohibited from participating in GPO contracts, and drugs administered in those facilities do not generate margins for GPOs (Health Resources & Services Administration, 2024). Nondisproportionate share 340B facilities and non-340B facilities can participate in a GPO.

For Medicaid, we classified all drug spending as non-340B-discounted because providers do not receive 340B price discounts when buying units that are administered to Medicaid beneficiaries.^34^

We used the IQVIA NSP major class variable to identify oncology drugs, immune modulators, and all others therapeutic areas. Similarly, we used the IQVIA NSP acute-chronic variable to determine the type of condition treated. A few drugs were not classified as acute or chronic by IQVIA and we did not include them in the analysis of acute and chronic conditions.

## 3.4 Monte Carlo Analysis

We conducted a Monte Carlo analysis to quantify the sampling error in our data and generate empirical 95 percent confidence intervals for our main results. We resampled the original dataset 10,000 times, and for each resample, we recalculated the weights and the primary outputs of the analysis. Each resampled dataset was constructed by randomly drawing from the original dataset with replacement until an equally sized dataset was acquired. For each analytic output (e.g., margins, retained portion of net spending), we calculated the 2.5^th^ and 97.5^th^ percentiles across the 10,000 estimates and used these to form a 95 percent confidence interval.

15 Original biologics refer to biologics approved through the 351(a) pathway. Biosimilars are biologics approved through the 351(k) pathway.

16 These reimbursement rates are published in separate Average Sales Price (ASP) files (Centers for Medicare & Medicaid Services, 2020-2022).

17 In this study, we use both “utilization” and “drug quantity” to refer to the amount of the drug administered, for which the payer and beneficiary submit payments (i.e., spending) that get distributed through the supply chain.

18 The VA negotiates this price with manufacturers on behalf of direct federal purchasers. The price is determined through negotiation, but statute imposes certain limitations. For example, “[d]uring a multiyear contract period, an FSS price may not increase faster than the net price charged to the most-favored commercial customer” (Congressional Budget Office, 2021).

19 As stated above, we studied all outpatient settings. This included, for example, “hospital outpatient departments, rural health clinics, renal dialysis facilities, outpatient rehabilitation facilities, comprehensive outpatient rehabilitation facilities, Federally Qualified Health Centers and community mental health centers” (ResDAC, 2020-2022).

20 We partitioned the full target population of drug spending into strata defined by unique combinations of year, payer (Medicare or Medicaid), provider type (outpatient or physician), HCPCS code, and 340B discount status. Of the HCPCS codes with no sample data, miscellaneous drugs made up 43 percent (n=87 HCPCS codes), vaccines made up 12 percent (n=24), chemotherapy drugs made up 9 percent (n=18), radiopharmaceuticals made up 8 percent (n=17), clotting factors made up 8 percent (n=16), stem cell therapies made up 5 percent (n=10), and immunoglobulins made up 4 percent (n=5). See Appendix A.2 for more details.

21 While our study is limited to Medicare Part B and Medicaid beneficiaries, claims submitted to these public payers often include additional spending by third-party payers. To capture the full reimbursement price to healthcare providers and to avoid underestimating their margins, we summed all payments listed on the claim, including other payers and the beneficiary.

22 This is a reasonable assumption as Medicare Part B primarily reimburses based on the average sales prices (ASPs) (Centers for Medicare & Medicaid Services, 2020-2022), which are publicly available and are the same for outpatient facilities and physician offices.

23 We used the sample weights to account for physician office drug spending and quantities sold. Although drug-level data were not available in the FFS Carrier claims data file, total spending by year, HCPCS, and 340B status were available. We included total dollars spent at physician offices in the appropriate strata when estimating the universe of Medicare Part B drug spending. See APPENDIX A for more details.

24 This is a reasonable assumption. For example, a Congressional Budget Office report found that, in the retail drug setting, the pre-rebate standardized price to Medicare Part D was $525 for top-selling brand drugs, compared to $517 for Medicaid (Congressional Budget Office, 2021).

25 To impute Medicaid prices, we matched 11-digit NDCs in the Medicaid claims sample to 11-digit NDCs in the Medicare Part B FFS Outpatient sample. For records that did not have a matching 11-digit NDC, we matched instead on 9-digit NDC and used the weighted average provider sales price per quantity of drug (i.e., per quantity of the 9-digit NDC).

26 For each claim, the listed facility’s 340B status was determined by matching to HRSA’s public listing of 340B facilities (Health Resources & Services Administration, 2024).

27 The IQVIA NSP dataset provides different invoice prices by distribution channel. The “clinic” channel captures all outpatient facilities and physician offices. For n=8 drugs, sales in clinics were not captured in NSP. In these cases, we substituted the average NSP invoice price in non-federal hospitals (n=4), mail pharmacies (n=3), or long-term care facilities (n=1).

28 Like the AMP, our estimate of the manufacturer’s net sales price on non-340B-discounted units represents payment to the manufacturer for the drug, after accounting for discounts to the wholesaler. The AMP, however, is not shown in Figure 2 because it may include other discounts we have not estimated (e.g., rebates to the PBM on drugs that are sold in both retail and non-retail settings).

29 We generally expected the NSP price to be higher than the best price offered by the manufacturer, as the NSP price reflects wholesaler markups and does not account for off-invoice discounts or rebates that may be offered by the manufacturer. Nonetheless, when a lower NSP price is available, it improves the estimate of the 340B discount.

30 In our stylized model, we assumed the wholesaler pays all of the GPO administrative fees. In reality, these per-drug fees are likely paid both by wholesalers and manufacturers, but the impact of these flows is small because they represent relatively low dollar amounts.

31 The two point estimates from these sources are therefore (1.22+2.25)/2 = 1.735 percent and 1.7 percent. The average of these point estimates is 1.7175 percent.

32 If the drug had a strength expressed as a fraction (e.g., 1 mg/100 mL), then we expressed the drug quantity in terms of the denominator unit (e.g., mL). In almost all other cases, we expressed the drug quantity in terms of the numerator unit.

33 As described in section 3, non-340B-discounted drug purchases are made both by 340B facilities (for drugs they administer to Medicaid beneficiaries) and by non-340B facilities. Purchases by both types of providers contribute to the total spending on non-340B-discounted drugs.

34 For units sold to Medicaid beneficiaries, manufacturers pay rebates to the Medicaid Drug Rebate Program. These same units are not eligible for 340B discounts to prevent manufacturers from paying duplicate discounts (Health Resources & Services Administration, 2020).