# 2 BACKGROUND

This study estimates the distribution of net spending by the payer and beneficiary on provider-administered drugs across four pharmaceutical supply chain entities. We briefly discuss the roles of these supply chain entities below.

## 2.1 Manufacturers

Drug manufacturers incur raw material and production costs of making pharmaceutical drugs, as well as the costs of research and development. Manufacturers establish the WAC or list price at which they sell a drug to wholesalers. They often pay out additional fees, discounts, and rebates to other supply chain entities, so that their net revenue from a drug is under the WAC price. Manufacturers generally have more power to set drug prices when they are the sole supplier of the drug market, which is often the case for branded drugs or original biologics.

## 2.2 Wholesalers

Wholesalers acquire drugs from manufacturers at their WAC price, which is offset by distribution fees and discounts that the manufacturer pays to the wholesaler, leading, in many cases, to a net acquisition cost lower than the published WAC. They sell to providers at negotiated prices, which are often based on the average wholesale price (AWP)—another price benchmark that is generally 20 percent more than the WAC for brand drugs, but varies more for generic drugs (Miller, et al., 2019).

## 2.3 Providers

Healthcare providers include hospital outpatient facilities, physician offices, standalone clinics, home healthcare, and other settings offering outpatient services. They acquire drugs from wholesalers or directly from manufacturers at negotiated contract prices.

The 340B Drug Pricing Program under Medicare allows eligible safety-net hospitals to purchase drugs at a discounted rate (Clark & Puthiyath, 2022). Safety-net hospitals, including critical access and disproportionate share hospitals, serve lower-income or underserved populations. The manufacturer bears this discount and will often pay it in the form of a chargeback to the wholesaler. 340B discounts include a minimum statutory discount rate of 23.1 percent for brand drugs, 17.1 percent for blood clotting factors and drugs approved only for pediatric indications, and 13 percent for generic drugs (Medicaid.gov, 2024; Dolan, 2019). These discount rates are applied to the average manufacturer price (AMP), which generally includes a wide range of rebates and discounts for drugs not primarily sold through retail pharmacies (Pew, 2017). For brand drugs, if the computed discounted price is still higher than the best price that the manufacturer offers to its most favored customer, then the 340B discount is increased further to match the best price. For both brands and generics, an additional inflationary component lowers the drug’s 340B price if the drug price rises faster than the rate of inflation. Vaccines comprise the largest group of drug products excluded from the 340B program. Drug units that 340B facilities administer to Medicaid beneficiaries are generally not eligible for 340B-discounted pricing because the manufacturer already pays a rebate to the Medicaid Drug Rebate Program (Health Resources & Services Administration, 2020).

## 2.4 Group Purchasing Organizations

Group purchasing organizations (GPOs) negotiate contract prices with suppliers (manufacturers or wholesalers) on behalf of groups of healthcare providers. They use the combined purchasing power of their provider members to negotiate favorable pricing and terms.

Most GPOs do not charge providers a membership fee for access to GPO-negotiated prices (Mulcahy & Kareddy, 2021). They generate profits through administrative fees charged to suppliers as a percentage of the drug price (Cardinal Health Specialty Solutions, 2020; Oakley, 2022; Mulcahy & Kareddy, 2021). GPOs conduct these negotiations with both manufacturers and wholesalers, which are incentivized to join GPOs and pay the administrative fees because they can access national contracts, which can generate large sales volume and have less administrative burden than setting up individual contracts with each provider. When a wholesaler sells a drug that is under a GPO contract price negotiated by the manufacturer, the wholesaler can use a chargeback process with the manufacturer to recoup losses if the contract sales price was lower than the wholesaler’s original acquisition cost.

GPOs are exempted by a safe harbor provision from the Federal anti-kickback statute [42 U.S.C. § 1320a-7b(b)], which “prohibits the knowing and willful payment of ‘remuneration’ to induce or reward patient referrals or the generation of business involving any item or service payable by the Federal health care programs” (U.S. Department of Health and Human Services, n.d.). To be eligible for safe harbor, GPOs must either charge vendors an administrative fee of 3 percent or less or include the administrative fee in their written contract with the vendor.

Certain types of 340B facilities are prohibited from membership in GPOs, including disproportionate share hospitals, children’s hospitals, and free-standing cancer hospitals (Health Resources & Services Administration, 2024).

## 2.5 Payers

In this study, we define total net spending to include payments made by public insurance (Medicare or Medicaid), the beneficiary, and any supplemental insurance. Drugs administered in physician offices and outpatient settings are covered under Medicare Part B—including injectables, clotting factors, and some vaccines, among others. We used Medicaid claims for the same set of separately payable drugs to calculate flows and spending under Medicaid.

Under the Medicaid Drug Rebate Program (MDRP), participating manufacturers pay states a rebate that is based on drug utilization in exchange for Medicaid coverage of their drugs (Centers for Medicare & Medicaid Services, 2024). Federal regulation stipulates how the Medicaid drug rebate is calculated. The Medicaid rebate amount per drug unit is very similar to the 340B discount per drug unit.