# 1 INTRODUCTION AND STUDY OBJECTIVES

This study estimates gross and net spending by payers and beneficiaries of provider-administered drugs. It also assesses how the net spending is distributed across the members of the pharmaceutical supply chain—including providers, wholesalers, group purchasing organizations (GPOs), and manufacturers. Our focus is on prescription drugs administered by healthcare professionals to Medicare Part B and Medicaid beneficiaries in outpatient or physician office settings. We only consider individually billed drugs and excluded drugs that are billed as part of a bundled group.^11^ Using public and proprietary data sources, we track the payments and quantities of individual drugs, which we define as drug products with a unique 9-digit National Drug Code (NDC), as they flow from manufacturer to patient. We also evaluate the margins earned by providers and wholesalers, both of which have a well-defined sales price and acquisition cost that can be directly compared.^12^ We define margins in dollar terms as the difference between an entity’s net sales price and net acquisition cost, and we also express this in percentage terms as a fraction of the net sales price. Because we calculate margins at the individual drug level, we are able to assess how certain drug characteristics affect margins and how payer and beneficiary spending is distributed to the supply chain members.

Increasing drug prices in U.S. markets have been a concern for many years. Analysis by the non-profit drug price research firm 46brooklyn shows that, among brand drugs with a price change, the median percentage change in the wholesale acquisition cost (WAC, or list price) of a drug was +7.9 percent to +9.0 percent in every year from 2012 to 2018 and +4.8 percent to +5.0 percent per year from 2019 through 2023 (46brooklyn, 2024). A study by the Assistant Secretary for Planning and Evaluation (ASPE) found that, from January 2022 to January 2023, there were over twice as many drugs with price increases (n=4,264) as there were with price decreases (n=1,599) (Bosworth, et al., 2023). While provider-administered outpatient drugs may make up a smaller fraction of total drug spending than self-administered retail drugs,^13^ one study found that, from 2008-2021, “Medicare fee-for-service (FFS) Part B drug spending per enrollee grew on average at 9.2 percent annually, [which is] more than triple the rate in Part D (2.6 percent)” (Nguyen, et al., 2023).

This study aims to answer the following research questions:

1. How is total net spending by payers and beneficiaries distributed to the members of the supply chains for individually billed drugs that are administered by healthcare professionals to Medicare or Medicaid beneficiaries in outpatient facilities and physician offices?
2. What are the margins of supply chain intermediaries (i.e., wholesalers and providers) on these outpatient drugs administered to Medicare and Medicaid beneficiaries?
3. How do the distributions of net spending and margins vary across the following drug subgroups:
  a. Generic small molecule drugs versus brand name small molecule drugs.
  b. Biosimilar biologics versus original biologics.
  c. Whether the drug or product faces competition in the market.^14^
  d. Whether the drug is or is not eligible for 340B discounted pricing.
  e. The therapeutic area of the drug.
  f. Whether the drug treats an acute condition or a chronic condition.
4. What trends have emerged in supply chain entities’ margins and in the distribution of payer and beneficiary net spending to those entities from 2020-2022? Have these trends varied across the drug product subgroups listed above?

11 Roehrig and Turner estimated that, in 2020, non-retail drug spending by all payers made up 31.1 percent of all drug spending (2022). Of the 31.1 percent, our study focuses on the subset of non-retail drug spending that is separately payable. We did not analyze bundled payments for which drug costs cannot be disaggregated from other costs like diagnostic testing, therapeutic services, room fees, etc.

12 We did not calculate margins for GPOs because they do not pay and are not paid for the full cost of the drug, which makes it difficult to define their net acquisition cost and net sales price.

13 For example, CMS reported total spending of $481 billion in Part D in 2022 (Centers for Medicare & Medicaid Services, 2024b), compared to $43.6 billion in Part B (excluding Medicare Advantage) in 2022 (Centers for Medicare & Medicaid Services, 2024c).

14 Among small molecules, we defined markets with multi-source drugs as competitive and markets with single-source drugs as noncompetitive. For biologics, we defined markets with an original biologic and at least one biosimilar competitor as “competitive” and markets in which the original biologic has no marketed biosimilars as noncompetitive.