# APPENDIX B SUPPLEMENTAL TABLES

Table B-1 Sample Characteristics, by Year

Year | Drug Group | Spending in Sample (Billion 2023 $) | Number of Drugs | Number of HCPCS Codes
2020 | All drugs | $11.61 | 1,528 | 427
2021 | All drugs | $13.07 | 1,629 | 468
2022 | All drugs | $14.04 | 1,685 | 466
2020 | Small molecules, generic | $0.17 | 994 | 189
2021 | Small molecules, generic | $0.19 | 1,047 | 196
2022 | Small molecules, generic | $0.23 | 1,120 | 198
2020 | Small molecules, brand | $1.70 | 284 | 165
2021 | Small molecules, brand | $1.85 | 301 | 182
2022 | Small molecules, brand | $1.81 | 272 | 164
2020 | Biosimilars | $0.38 | 22 | 13
2021 | Biosimilars | $0.69 | 26 | 15
2022 | Biosimilars | $0.74 | 29 | 17
2020 | Original biologics | $9.36 | 228 | 131
2021 | Original biologics | $10.35 | 255 | 143
2022 | Original biologics | $11.26 | 264 | 155
2020 | Competitive small molecules (multi-source) | $0.34 | 1,096 | 201
2021 | Competitive small molecules (multi-source) | $0.39 | 1,139 | 214
2022 | Competitive small molecules (multi-source) | $0.76 | 1,197 | 212
2020 | Noncompetitive small molecules (single source) | $1.53 | 181 | 116
2021 | Noncompetitive small molecules (single source) | $1.65 | 209 | 129
2022 | Noncompetitive small molecules (single source) | $1.28 | 195 | 118
2020 | Competitive biologics | $1.58 | 27 | 17
2021 | Competitive biologics | $1.41 | 31 | 19
2022 | Competitive biologics | $1.23 | 34 | 21
2020 | Noncompetitive biologics | $8.16 | 223 | 127
2021 | Noncompetitive biologics | $9.62 | 250 | 139
2022 | Noncompetitive biologics | $10.76 | 259 | 151
2020 | 340B drug sales | $7.95 | 1,437 | 422
2021 | 340B drug sales | $8.88 | 1,532 | 462
2022 | 340B drug sales | $9.60 | 1,599 | 462
2020 | Non-340B drug sales | $3.67 | 930 | 341
2021 | Non-340B drug sales | $4.20 | 946 | 363
2022 | Non-340B drug sales | $4.43 | 969 | 378
2020 | Oncology | $6.82 | 377 | 110
2021 | Oncology | $8.01 | 406 | 125
2022 | Oncology | $8.85 | 407 | 123
2020 | Other therapeutic areas | $4.79 | 1,151 | 318
2021 | Other therapeutic areas | $5.06 | 1,223 | 344
2022 | Other therapeutic areas | $5.19 | 1,278 | 344
2020 | Acute conditions | $8.72 | 1,195 | 325
2021 | Acute conditions | $10.00 | 1,262 | 357
2022 | Acute conditions | $10.78 | 1,287 | 353
2020 | Chronic conditions | $2.86 | 327 | 105
2021 | Chronic conditions | $3.03 | 361 | 112
2022 | Chronic conditions | $3.19 | 392 | 115

Note: Six drugs had an unclassified condition type (neither acute nor chronic).

Table B-2 Data for Figure 3 Distribution to Supply Chain of Payer-Beneficiary Net Spending on All Drugs

Year | Drug Group | Entity | Amount of Net Spending Retained (Billion 2023 $) | Percentage of Net Spending Retained
2020 | All Drugs | Manufacturer | $31.09 | 74.24%
2020 | All Drugs | Wholesaler | $1.53 | 3.65%
2020 | All Drugs | Provider | $8.79 | 21.00%
2020 | All Drugs | GPO | $0.46 | 1.11%
2021 | All Drugs | Manufacturer | $33.00 | 75.79%
2021 | All Drugs | Wholesaler | $1.44 | 3.30%
2021 | All Drugs | Provider | $8.60 | 19.76%
2021 | All Drugs | GPO | $0.50 | 1.15%
2022 | All Drugs | Manufacturer | $32.98 | 74.15%
2022 | All Drugs | Wholesaler | $1.12 | 2.52%
2022 | All Drugs | Provider | $9.88 | 22.22%
2022 | All Drugs | GPO | $0.49 | 1.11%

Table B-3 Data for Figure 4 Providers and Wholesalers’ Margins on All Drug

Year | Drug Group | Entity | Margin (Billion 2023 $) | Margin Percentage
2020 | All Drugs | Wholesaler | $1.53 | 4.53%
2020 | All Drugs | Provider | $8.79 | 20.46%
2021 | All Drugs | Wholesaler | $1.44 | 4.01%
2021 | All Drugs | Provider | $8.60 | 19.13%
2022 | All Drugs | Wholesaler | $1.12 | 3.15%
2022 | All Drugs | Provider | $9.88 | 21.52%

Table B-4 Data for Figure 5 Distribution to Supply Chain of Payer-Beneficiary Net Spending on Brand and Generic Small Molecule Drugs

Year | Brand-Generic Status | Entity | Amount of Net Spending Retained (Billion 2023 $) | Percentage of Net Spending Retained
2020 | Small Molecule Brand | Manufacturer | $3.67 | 60.53%
2020 | Small Molecule Brand | Wholesaler | $0.18 | 3.03%
2020 | Small Molecule Brand | Provider | $2.16 | 35.54%
2020 | Small Molecule Brand | GPO | $0.06 | 0.91%
2020 | Small Molecule Generic | Manufacturer | $0.43 | 38.98%
2020 | Small Molecule Generic | Wholesaler | $0.04 | 3.33%
2020 | Small Molecule Generic | Provider | $0.63 | 56.98%
2020 | Small Molecule Generic | GPO | $0.01 | 0.70%
2021 | Small Molecule Brand | Manufacturer | $3.87 | 66.57%
2021 | Small Molecule Brand | Wholesaler | $0.18 | 3.16%
2021 | Small Molecule Brand | Provider | $1.70 | 29.24%
2021 | Small Molecule Brand | GPO | $0.06 | 1.02%
2021 | Small Molecule Generic | Manufacturer | $0.40 | 34.24%
2021 | Small Molecule Generic | Wholesaler | $0.04 | 3.33%
2021 | Small Molecule Generic | Provider | $0.72 | 61.77%
2021 | Small Molecule Generic | GPO | $0.01 | 0.66%
2022 | Small Molecule Brand | Manufacturer | $3.40 | 63.78%
2022 | Small Molecule Brand | Wholesaler | $0.10 | 1.80%
2022 | Small Molecule Brand | Provider | $1.78 | 33.49%
2022 | Small Molecule Brand | GPO | $0.05 | 0.93%
2022 | Small Molecule Generic | Manufacturer | $0.40 | 34.98%
2022 | Small Molecule Generic | Wholesaler | $0.04 | 3.13%
2022 | Small Molecule Generic | Provider | $0.70 | 61.23%
2022 | Small Molecule Generic | GPO | $0.01 | 0.66%

Table B-5 Data for Figure 6 Providers and Wholesalers’ Margins on Brand and Generic Small Molecule Drugs

Year | Brand-Generic Status | Entity | Margin (Billion 2023 $) | Margin Percentage
2020 | Small Molecule Brand | Wholesaler | $0.18 | 4.51%
2020 | Small Molecule Brand | Provider | $2.16 | 34.31%
2020 | Small Molecule Generic | Wholesaler | $0.04 | 7.25%
2020 | Small Molecule Generic | Provider | $0.63 | 54.97%
2021 | Small Molecule Brand | Wholesaler | $0.18 | 4.25%
2021 | Small Molecule Brand | Provider | $1.70 | 27.92%
2021 | Small Molecule Generic | Wholesaler | $0.04 | 8.09%
2021 | Small Molecule Generic | Provider | $0.72 | 59.63%
2022 | Small Molecule Brand | Wholesaler | $0.10 | 2.60%
2022 | Small Molecule Brand | Provider | $1.78 | 32.30%
2022 | Small Molecule Generic | Wholesaler | $0.04 | 7.58%
2022 | Small Molecule Generic | Provider | $0.70 | 59.36%

Table B-6 Data for Figure 7 Distribution to Supply Chain of Payer-Beneficiary Net Spending on Original Biologics and Biosimilars

Year | Type of Biologic | Entity | Amount of Net Spending Retained (Billion 2023 $) | Percentage of Net Spending Retained
2020 | Biosimilar | Manufacturer | $0.95 | 64.63%
2020 | Biosimilar | Wholesaler | $0.05 | 3.60%
2020 | Biosimilar | Provider | $0.45 | 30.79%
2020 | Biosimilar | GPO | $0.01 | 0.97%
2020 | Original Biologic | Manufacturer | $26.03 | 78.35%
2020 | Original Biologic | Wholesaler | $1.25 | 3.77%
2020 | Original Biologic | Provider | $5.55 | 16.71%
2020 | Original Biologic | GPO | $0.39 | 1.17%
2021 | Biosimilar | Manufacturer | $1.33 | 62.45%
2021 | Biosimilar | Wholesaler | $0.09 | 4.40%
2021 | Biosimilar | Provider | $0.68 | 32.14%
2021 | Biosimilar | GPO | $0.02 | 1.02%
2021 | Original Biologic | Manufacturer | $27.41 | 79.57%
2021 | Original Biologic | Wholesaler | $1.12 | 3.26%
2021 | Original Biologic | Provider | $5.51 | 15.98%
2021 | Original Biologic | GPO | $0.41 | 1.19%
2022 | Biosimilar | Manufacturer | $1.37 | 67.99%
2022 | Biosimilar | Wholesaler | $0.09 | 4.33%
2022 | Biosimilar | Provider | $0.53 | 26.53%
2022 | Biosimilar | GPO | $0.02 | 1.14%
2022 | Original Biologic | Manufacturer | $27.82 | 77.28%
2022 | Original Biologic | Wholesaler | $0.90 | 2.50%
2022 | Original Biologic | Provider | $6.86 | 19.07%
2022 | Original Biologic | GPO | $0.41 | 1.15%

Table B-7 Data for Figure 8 Providers and Wholesalers’ Margins on Original Biologics and Biosimilars

Year | Type of Biologic | Entity | Margin (Billion 2023 $) | Margin Percentage
2020 | Biosimilar | Wholesaler | $0.05 | 5.07%
2020 | Biosimilar | Provider | $0.45 | 29.95%
2020 | Original Biologic | Wholesaler | $1.25 | 4.46%
2020 | Original Biologic | Provider | $5.55 | 16.32%
2021 | Biosimilar | Wholesaler | $0.09 | 6.16%
2021 | Biosimilar | Provider | $0.68 | 30.71%
2021 | Original Biologic | Wholesaler | $1.12 | 3.80%
2021 | Original Biologic | Provider | $5.51 | 15.53%
2022 | Biosimilar | Wholesaler | $0.09 | 5.48%
2022 | Biosimilar | Provider | $0.53 | 24.86%
2022 | Original Biologic | Wholesaler | $0.90 | 3.02%
2022 | Original Biologic | Provider | $6.86 | 18.51%

Table B-8 Data for Figure 9 Distribution to Supply Chain of Payer-Beneficiary Net Spending on Small Molecule Drugs, Competitive vs. Noncompetitive Markets

Year | Competition Status | Entity | Amount of Net Spending Retained (Billion 2023 $) | Percentage of Net Spending Retained
2020 | Noncompetitive Small Molecule | Manufacturer | $3.17 | 68.23%
2020 | Noncompetitive Small Molecule | Wholesaler | $0.12 | 2.66%
2020 | Noncompetitive Small Molecule | Provider | $1.31 | 28.12%
2020 | Noncompetitive Small Molecule | GPO | $0.05 | 0.98%
2020 | Competitive Small Molecule | Manufacturer | $0.93 | 36.90%
2020 | Competitive Small Molecule | Wholesaler | $0.10 | 3.83%
2020 | Competitive Small Molecule | Provider | $1.48 | 58.58%
2020 | Competitive Small Molecule | GPO | $0.02 | 0.68%
2021 | Noncompetitive Small Molecule | Manufacturer | $3.31 | 70.55%
2021 | Noncompetitive Small Molecule | Wholesaler | $0.11 | 2.25%
2021 | Noncompetitive Small Molecule | Provider | $1.23 | 26.17%
2021 | Noncompetitive Small Molecule | GPO | $0.05 | 1.03%
2021 | Competitive Small Molecule | Manufacturer | $0.96 | 41.97%
2021 | Competitive Small Molecule | Wholesaler | $0.12 | 5.12%
2021 | Competitive Small Molecule | Provider | $1.19 | 52.09%
2021 | Competitive Small Molecule | GPO | $0.02 | 0.83%
2022 | Noncompetitive Small Molecule | Manufacturer | $2.37 | 66.43%
2022 | Noncompetitive Small Molecule | Wholesaler | $0.07 | 2.07%
2022 | Noncompetitive Small Molecule | Provider | $1.09 | 30.53%
2022 | Noncompetitive Small Molecule | GPO | $0.03 | 0.98%
2022 | Competitive Small Molecule | Manufacturer | $1.42 | 49.14%
2022 | Competitive Small Molecule | Wholesaler | $0.06 | 1.99%
2022 | Competitive Small Molecule | Provider | $1.39 | 48.10%
2022 | Competitive Small Molecule | GPO | $0.02 | 0.77%

Table B-9 Data for Figure 10: Providers and Wholesalers’ Margins on Small Molecule Drugs, Competitive vs. Noncompetitive Markets

Year | Competition Status | Entity | Margin (Billion 2023 $) | Margin Percentage
2020 | Noncompetitive Small Molecule | Wholesaler | $0.12 | 3.60%
2020 | Noncompetitive Small Molecule | Provider | $1.31 | 27.26%
2020 | Competitive Small Molecule | Wholesaler | $0.10 | 8.49%
2020 | Competitive Small Molecule | Provider | $1.48 | 56.12%
2021 | Noncompetitive Small Molecule | Wholesaler | $0.11 | 2.94%
2021 | Noncompetitive Small Molecule | Provider | $1.23 | 25.24%
2021 | Competitive Small Molecule | Wholesaler | $0.12 | 9.58%
2021 | Competitive Small Molecule | Provider | $1.19 | 48.98%
2022 | Noncompetitive Small Molecule | Wholesaler | $0.07 | 2.87%
2022 | Noncompetitive Small Molecule | Provider | $1.09 | 29.47%
2022 | Competitive Small Molecule | Wholesaler | $0.06 | 3.64%
2022 | Competitive Small Molecule | Provider | $1.39 | 46.43%

Table B-10 Data for Figure 11: Distribution to Supply Chain of Payer-Beneficiary Net Spending per Package on Brand and Generic Small Molecule Drugs, Competitive vs. Noncompetitive Markets

Year | Competition Status | Drug Type | Entity | Net Spending Retained per Package (2023 $)
2020 | Competitive | Brand Small Molecule | Manufacturer | $327.76
2020 | Competitive | Brand Small Molecule | Wholesaler | $6.14
2020 | Competitive | Brand Small Molecule | Provider | $142.75
2020 | Competitive | Brand Small Molecule | GPO | $2.68
2020 | Competitive | Generic Small Molecule | Manufacturer | $25.65
2020 | Competitive | Generic Small Molecule | Wholesaler | $2.00
2020 | Competitive | Generic Small Molecule | Provider | $30.49
2020 | Competitive | Generic Small Molecule | GPO | $0.33
2020 | Noncompetitive | Brand Small Molecule | Manufacturer | $865.15
2020 | Noncompetitive | Brand Small Molecule | Wholesaler | $37.02
2020 | Noncompetitive | Brand Small Molecule | Provider | $379.59
2020 | Noncompetitive | Brand Small Molecule | GPO | $7.60
2020 | Noncompetitive | Generic Small Molecule | Manufacturer | $210.13
2020 | Noncompetitive | Generic Small Molecule | Wholesaler | $17.97
2020 | Noncompetitive | Generic Small Molecule | Provider | $212.10
2020 | Noncompetitive | Generic Small Molecule | GPO | $2.89
2021 | Competitive | Brand Small Molecule | Manufacturer | $288.13
2021 | Competitive | Brand Small Molecule | Wholesaler | $6.84
2021 | Competitive | Brand Small Molecule | Provider | $124.07
2021 | Competitive | Brand Small Molecule | GPO | $2.46
2021 | Competitive | Generic Small Molecule | Manufacturer | $14.43
2021 | Competitive | Generic Small Molecule | Wholesaler | $1.34
2021 | Competitive | Generic Small Molecule | Provider | $22.62
2021 | Competitive | Generic Small Molecule | GPO | $0.23
2021 | Noncompetitive | Brand Small Molecule | Manufacturer | $899.12
2021 | Noncompetitive | Brand Small Molecule | Wholesaler | $27.75
2021 | Noncompetitive | Brand Small Molecule | Provider | $366.59
2021 | Noncompetitive | Brand Small Molecule | GPO | $7.79
2021 | Noncompetitive | Generic Small Molecule | Manufacturer | $118.37
2021 | Noncompetitive | Generic Small Molecule | Wholesaler | $10.28
2021 | Noncompetitive | Generic Small Molecule | Provider | $112.82
2021 | Noncompetitive | Generic Small Molecule | GPO | $1.57
2022 | Competitive | Brand Small Molecule | Manufacturer | $546.22
2022 | Competitive | Brand Small Molecule | Wholesaler | $3.62
2022 | Competitive | Brand Small Molecule | Provider | $341.48
2022 | Competitive | Brand Small Molecule | GPO | $4.29
2022 | Competitive | Generic Small Molecule | Manufacturer | $12.09
2022 | Competitive | Generic Small Molecule | Wholesaler | $0.91
2022 | Competitive | Generic Small Molecule | Provider | $21.40
2022 | Competitive | Generic Small Molecule | GPO | $0.18
2022 | Noncompetitive | Brand Small Molecule | Manufacturer | $801.97
2022 | Noncompetitive | Brand Small Molecule | Wholesaler | $30.98
2022 | Noncompetitive | Brand Small Molecule | Provider | $483.99
2022 | Noncompetitive | Brand Small Molecule | GPO | $7.28
2022 | Noncompetitive | Generic Small Molecule | Manufacturer | $82.74
2022 | Noncompetitive | Generic Small Molecule | Wholesaler | $2.68
2022 | Noncompetitive | Generic Small Molecule | Provider | $74.03
2022 | Noncompetitive | Generic Small Molecule | GPO | $1.04

Table B-11 Data for Figure 12: Distribution to Supply Chain of Payer-Beneficiary Net Spending on Biologics, Competitive vs. Noncompetitive Markets

Year | Competition Status | Entity | Amount of Net Spending Retained (Billion 2023 $) | Percentage of Net Spending Retained
2020 | Competitive Biologics | Manufacturer | $4.57 | 68.22%
2020 | Competitive Biologics | Wholesaler | $0.22 | 3.31%
2020 | Competitive Biologics | Provider | $1.84 | 27.48%
2020 | Competitive Biologics | GPO | $0.07 | 0.98%
2020 | Noncompetitive Biologics | Manufacturer | $22.42 | 80.05%
2020 | Noncompetitive Biologics | Wholesaler | $1.09 | 3.88%
2020 | Noncompetitive Biologics | Provider | $4.17 | 14.87%
2020 | Noncompetitive Biologics | GPO | $0.34 | 1.20%
2021 | Competitive Biologics | Manufacturer | $3.75 | 70.20%
2021 | Competitive Biologics | Wholesaler | $0.19 | 3.55%
2021 | Competitive Biologics | Provider | $1.34 | 25.19%
2021 | Competitive Biologics | GPO | $0.06 | 1.06%
2021 | Noncompetitive Biologics | Manufacturer | $24.99 | 80.01%
2021 | Noncompetitive Biologics | Wholesaler | $1.03 | 3.28%
2021 | Noncompetitive Biologics | Provider | $4.84 | 15.51%
2021 | Noncompetitive Biologics | GPO | $0.38 | 1.20%
2022 | Competitive Biologics | Manufacturer | $3.07 | 72.04%
2022 | Competitive Biologics | Wholesaler | $0.15 | 3.53%
2022 | Competitive Biologics | Provider | $0.99 | 23.28%
2022 | Competitive Biologics | GPO | $0.05 | 1.15%
2022 | Noncompetitive Biologics | Manufacturer | $26.11 | 77.38%
2022 | Noncompetitive Biologics | Wholesaler | $0.84 | 2.48%
2022 | Noncompetitive Biologics | Provider | $6.41 | 18.98%
2022 | Noncompetitive Biologics | GPO | $0.39 | 1.15%

Table B-12 Data for Figure 13: Providers and Wholesalers’ Margins on Biologics, Competitive vs. Noncompetitive Markets

Year | Competition Status | Entity | Margin (Billion 2023 $) | Margin Percentage
2020 | Competitive Biologics | Wholesaler | $0.22 | 4.46%
2020 | Competitive Biologics | Provider | $1.84 | 26.73%
2020 | Noncompetitive Biologics | Wholesaler | $1.09 | 4.49%
2020 | Noncompetitive Biologics | Provider | $4.17 | 14.53%
2021 | Competitive Biologics | Wholesaler | $0.19 | 4.57%
2021 | Competitive Biologics | Provider | $1.34 | 24.23%
2021 | Noncompetitive Biologics | Wholesaler | $1.03 | 3.81%
2021 | Noncompetitive Biologics | Provider | $4.84 | 15.07%
2022 | Competitive Biologics | Wholesaler | $0.15 | 4.34%
2022 | Competitive Biologics | Provider | $0.99 | 22.01%
2022 | Noncompetitive Biologics | Wholesaler | $0.84 | 3.00%
2022 | Noncompetitive Biologics | Provider | $6.41 | 18.45%

Table B-13 Data for Figure 14: Distribution to Supply Chain of Payer-Beneficiary Net Spending per Package on Original Biologics and Biosimilars, Competitive vs. Noncompetitive Markets

Year | Competition Status | Type of Biologic | Entity | Net Spending Retained per Package (2023 $)
2020 | Competitive | Original Biologic | Manufacturer | $961.99
2020 | Competitive | Original Biologic | Wholesaler | $62.21
2020 | Competitive | Original Biologic | Provider | $418.92
2020 | Competitive | Original Biologic | GPO | $8.64
2020 | Competitive | Biosimilar | Manufacturer | $775.42
2020 | Competitive | Biosimilar | Wholesaler | $55.59
2020 | Competitive | Biosimilar | Provider | $519.62
2020 | Competitive | Biosimilar | GPO | $7.46
2020 | Noncompetitive | Original Biologic | Manufacturer | $482.03
2020 | Noncompetitive | Original Biologic | Wholesaler | $32.88
2020 | Noncompetitive | Original Biologic | Provider | $155.65
2020 | Noncompetitive | Original Biologic | GPO | $4.26
2021 | Competitive | Original Biologic | Manufacturer | $892.30
2021 | Competitive | Original Biologic | Wholesaler | $51.01
2021 | Competitive | Original Biologic | Provider | $258.15
2021 | Competitive | Original Biologic | GPO | $8.16
2021 | Competitive | Biosimilar | Manufacturer | $568.14
2021 | Competitive | Biosimilar | Wholesaler | $64.36
2021 | Competitive | Biosimilar | Provider | $493.05
2021 | Competitive | Biosimilar | GPO | $6.70
2021 | Noncompetitive | Original Biologic | Manufacturer | $575.63
2021 | Noncompetitive | Original Biologic | Wholesaler | $33.97
2021 | Noncompetitive | Original Biologic | Provider | $185.83
2021 | Noncompetitive | Original Biologic | GPO | $5.26
2022 | Competitive | Original Biologic | Manufacturer | $757.70
2022 | Competitive | Original Biologic | Wholesaler | $40.50
2022 | Competitive | Original Biologic | Provider | $296.85
2022 | Competitive | Original Biologic | GPO | $8.08
2022 | Competitive | Biosimilar | Manufacturer | $468.73
2022 | Competitive | Biosimilar | Wholesaler | $50.42
2022 | Competitive | Biosimilar | Provider | $324.00
2022 | Competitive | Biosimilar | GPO | $5.61
2022 | Noncompetitive | Original Biologic | Manufacturer | $469.63
2022 | Noncompetitive | Original Biologic | Wholesaler | $21.31
2022 | Noncompetitive | Original Biologic | Provider | $212.16
2022 | Noncompetitive | Original Biologic | GPO | $4.28

Table B-14 Data for Figure 15: Distribution to Supply Chain of Payer-Beneficiary Net Spending on All Drugs, by 340B Discount Status

Year | Discount Status | Entity | Amount of Net Spending Retained (Billion 2023 $) | Percentage of Net Spending Retained
2020 | 340B | Manufacturer | $8.63 | 66.94%
2020 | 340B | Wholesaler | $0.65 | 5.08%
2020 | 340B | Provider | $3.57 | 27.69%
2020 | 340B | GPO | $0.04 | 0.29%
2020 | Non-340B | Manufacturer | $22.46 | 77.49%
2020 | Non-340B | Wholesaler | $0.87 | 3.01%
2020 | Non-340B | Provider | $5.22 | 18.02%
2020 | Non-340B | GPO | $0.43 | 1.47%
2021 | 340B | Manufacturer | $9.16 | 67.31%
2021 | 340B | Wholesaler | $0.62 | 4.54%
2021 | 340B | Provider | $3.78 | 27.83%
2021 | 340B | GPO | $0.04 | 0.32%
2021 | Non-340B | Manufacturer | $23.85 | 79.64%
2021 | Non-340B | Wholesaler | $0.82 | 2.74%
2021 | Non-340B | Provider | $4.82 | 16.10%
2021 | Non-340B | GPO | $0.46 | 1.52%
2022 | 340B | Manufacturer | $9.22 | 59.57%
2022 | 340B | Wholesaler | $0.53 | 3.43%
2022 | 340B | Provider | $5.68 | 36.72%
2022 | 340B | GPO | $0.04 | 0.28%
2022 | Non-340B | Manufacturer | $23.77 | 81.93%
2022 | Non-340B | Wholesaler | $0.59 | 2.03%
2022 | Non-340B | Provider | $4.20 | 14.48%
2022 | Non-340B | GPO | $0.45 | 1.55%

Table B-15 Data for Figure 16: Providers and Wholesalers’ Margins on All Drugs, by 340B Discount Status

Year | Discount Status | Entity | Margin (Billion 2023 $) | Margin Percentage
2020 | 340B | Wholesaler | $0.65 | 7.05%
2020 | 340B | Provider | $3.57 | 27.69%
2020 | Non-340B | Wholesaler | $0.87 | 3.57%
2020 | Non-340B | Provider | $5.22 | 17.36%
2021 | 340B | Wholesaler | $0.62 | 6.32%
2021 | 340B | Provider | $3.78 | 27.83%
2021 | Non-340B | Wholesaler | $0.82 | 3.14%
2021 | Non-340B | Provider | $4.82 | 15.37%
2022 | 340B | Wholesaler | $0.53 | 5.44%
2022 | 340B | Provider | $5.68 | 36.72%
2022 | Non-340B | Wholesaler | $0.59 | 2.28%
2022 | Non-340B | Provider | $4.20 | 13.79%

Table B-16 Data for Figure 17: Distribution to Supply Chain of Payer-Beneficiary Net Spending on All Drugs, by Therapeutic Area

Year | Therapeutic Area | Entity | Amount of Net Spending Retained (Billion 2023 $) | Percentage of Net Spending Retained
2020 | All Other Therapeutic Areas | Manufacturer | $12.27 | 75.56%
2020 | All Other Therapeutic Areas | Wholesaler | $0.70 | 4.30%
2020 | All Other Therapeutic Areas | Provider | $3.07 | 18.90%
2020 | All Other Therapeutic Areas | GPO | $0.20 | 1.25%
2020 | Immune Modulators | Manufacturer | $4.44 | 72.54%
2020 | Immune Modulators | Wholesaler | $0.13 | 2.13%
2020 | Immune Modulators | Provider | $1.48 | 24.20%
2020 | Immune Modulators | GPO | $0.07 | 1.12%
2020 | Oncologics | Manufacturer | $14.38 | 73.68%
2020 | Oncologics | Wholesaler | $0.70 | 3.58%
2020 | Oncologics | Provider | $4.24 | 21.74%
2020 | Oncologics | GPO | $0.19 | 1.00%
2021 | All Other Therapeutic Areas | Manufacturer | $12.76 | 77.35%
2021 | All Other Therapeutic Areas | Wholesaler | $0.71 | 4.31%
2021 | All Other Therapeutic Areas | Provider | $2.81 | 17.03%
2021 | All Other Therapeutic Areas | GPO | $0.22 | 1.31%
2021 | Immune Modulators | Manufacturer | $4.82 | 76.11%
2021 | Immune Modulators | Wholesaler | $0.06 | 0.93%
2021 | Immune Modulators | Provider | $1.38 | 21.78%
2021 | Immune Modulators | GPO | $0.07 | 1.17%
2021 | Oncologics | Manufacturer | $15.42 | 74.45%
2021 | Oncologics | Wholesaler | $0.67 | 3.22%
2021 | Oncologics | Provider | $4.42 | 21.32%
2021 | Oncologics | GPO | $0.21 | 1.01%
2022 | All Other Therapeutic Areas | Manufacturer | $11.90 | 75.34%
2022 | All Other Therapeutic Areas | Wholesaler | $0.55 | 3.49%
2022 | All Other Therapeutic Areas | Provider | $3.14 | 19.91%
2022 | All Other Therapeutic Areas | GPO | $0.20 | 1.26%
2022 | Immune Modulators | Manufacturer | $4.99 | 77.23%
2022 | Immune Modulators | Wholesaler | $0.04 | 0.61%
2022 | Immune Modulators | Provider | $1.35 | 20.96%
2022 | Immune Modulators | GPO | $0.08 | 1.20%
2022 | Oncologics | Manufacturer | $16.09 | 72.42%
2022 | Oncologics | Wholesaler | $0.53 | 2.38%
2022 | Oncologics | Provider | $5.38 | 24.22%
2022 | Oncologics | GPO | $0.22 | 0.98%

Table B-17 Data for Figure 18: Providers and Wholesalers’ Margins on All Drugs, by Therapeutic Area

Year | Therapeutic Area | Entity | Margin (Billion 2023 $) | Margin Percentage
2020 | All Other Therapeutic Areas | Wholesaler | $0.70 | 5.16%
2020 | All Other Therapeutic Areas | Provider | $3.07 | 18.27%
2020 | Immune Modulators | Wholesaler | $0.13 | 2.77%
2020 | Immune Modulators | Provider | $1.48 | 23.62%
2020 | Oncologics | Wholesaler | $0.70 | 4.52%
2020 | Oncologics | Provider | $4.24 | 21.31%
2021 | All Other Therapeutic Areas | Wholesaler | $0.71 | 4.99%
2021 | All Other Therapeutic Areas | Provider | $2.81 | 16.26%
2021 | Immune Modulators | Wholesaler | $0.06 | 1.17%
2021 | Immune Modulators | Provider | $1.38 | 21.18%
2021 | Oncologics | Wholesaler | $0.67 | 4.03%
2021 | Oncologics | Provider | $4.42 | 20.85%
2022 | All Other Therapeutic Areas | Wholesaler | $0.55 | 4.20%
2022 | All Other Therapeutic Areas | Provider | $3.14 | 19.10%
2022 | Immune Modulators | Wholesaler | $0.04 | 0.76%
2022 | Immune Modulators | Provider | $1.35 | 20.26%
2022 | Oncologics | Wholesaler | $0.53 | 3.08%
2022 | Oncologics | Provider | $5.38 | 23.63%

Table B-18 Data for Figure 19: Distribution to Supply Chain of Payer-Beneficiary Net Spending on All Drugs, by Acute vs. Chronic Condition

Year | Type of Condition | Entity | Amount of Net Spending Retained (Billion 2023 $) | Percentage of Net Spending Retained
2020 | Acute | Manufacturer | $22.81 | 74.06%
2020 | Acute | Wholesaler | $1.28 | 4.15%
2020 | Acute | Provider | $6.38 | 20.70%
2020 | Acute | GPO | $0.34 | 1.09%
2020 | Chronic | Manufacturer | $8.16 | 74.73%
2020 | Chronic | Wholesaler | $0.24 | 2.18%
2020 | Chronic | Provider | $2.40 | 21.93%
2020 | Chronic | GPO | $0.13 | 1.16%
2021 | Acute | Manufacturer | $23.86 | 73.80%
2021 | Acute | Wholesaler | $1.19 | 3.69%
2021 | Acute | Provider | $6.93 | 21.42%
2021 | Acute | GPO | $0.35 | 1.09%
2021 | Chronic | Manufacturer | $8.95 | 81.47%
2021 | Chronic | Wholesaler | $0.25 | 2.26%
2021 | Chronic | Provider | $1.64 | 14.96%
2021 | Chronic | GPO | $0.14 | 1.31%
2022 | Acute | Manufacturer | $23.94 | 72.42%
2022 | Acute | Wholesaler | $0.98 | 2.97%
2022 | Acute | Provider | $7.78 | 23.55%
2022 | Acute | GPO | $0.35 | 1.06%
2022 | Chronic | Manufacturer | $8.77 | 79.03%
2022 | Chronic | Wholesaler | $0.14 | 1.27%
2022 | Chronic | Provider | $2.05 | 18.44%
2022 | Chronic | GPO | $0.14 | 1.25%

Table B-19 Data for Figure 20: Providers and Wholesalers’ Margins on All Drugs, by Acute vs. Chronic Condition

Year | Type of Condition | Entity | Margin (Billion 2023 $) | Margin Percentage
2020 | Acute | Wholesaler | $1.28 | 5.15%
2020 | Acute | Provider | $6.38 | 20.23%
2020 | Chronic | Wholesaler | $0.24 | 2.71%
2020 | Chronic | Provider | $2.40 | 21.18%
2021 | Acute | Wholesaler | $1.19 | 4.60%
2021 | Acute | Provider | $6.93 | 20.86%
2021 | Chronic | Wholesaler | $0.25 | 2.54%
2021 | Chronic | Provider | $1.64 | 14.23%
2022 | Acute | Wholesaler | $0.98 | 3.80%
2022 | Acute | Provider | $7.78 | 22.92%
2022 | Chronic | Wholesaler | $0.14 | 1.50%
2022 | Chronic | Provider | $2.05 | 17.59%