# APPENDIX A DETAILED METHODOLOGY

## A.1 Identifying the Target Population

The target population of drug spending included all Medicare Part B and Medicaid spending on individually billed drugs administered by healthcare professionals in outpatient settings or physician offices in 2020, 2021, and 2022. We restricted inclusion to Medicaid drugs with the same HCPCS codes reimbursed by Medicare and listed in the CMS Part B Crosswalk files (Centers for Medicare & Medicaid Services, 2020-2022). Spending by commercial healthcare plans was excluded from the study, as was Medicare Advantage spending.

To identify the total spending, we used the 100 percent Medicare FFS claims data (Carrier and Outpatient Hospital files) from 2020 to 2022.^46^ The FFS outpatient files contain claims for services provided in hospital outpatient departments. We excluded (a) claims with no Medicare payments; (b) claims where the drug was bundled with a service (i.e., we only included Outpatient Prospective Payment System status indicators of A, F, G, K, L or S); and (c) claims for Investigational Devices billed under Revenue Center code 0624. The FFS Carrier file contains claims for services provided in independent physician offices; in this file, we excluded claims with no Medicare or beneficiary payments. In both files, we only analyzed HCPCS codes listed in the CMS Part B HCPCS-NDC Crosswalks (Centers for Medicare & Medicaid Services, 2020-2022).

We also used the 100 percent Medicaid claims data to quantify spending on and use of in-scope drugs administered to Medicaid beneficiaries. We included only claims with HCPCS codes listed in the CMS Part B HCPCS-NDC Crosswalk file. For the drug sample, we further restricted inclusion to valid 11-digit NDCs where the labeler and package codes matched to CMS’s list of drugs that participate in the MDRP (Medicaid.gov, 2020-2022). We excluded (a) claims with missing or zero Medicaid payments; (b) MCO capitated payments, service tracking claims, and supplemental lump sum payments (i.e., we only included FFS claims and MCO encounters with claim types 1, 3, A, c, U, or W); and (c) payments where the Type of Service (TOS) code indicated services that were not delivered in an outpatient or physician office setting.

## A.2 Identifying the Sample and Study Population

We selected the sample of drugs based on data availability. Some drugs were not included in the sample because their information was suppressed (e.g., due to aggregating fewer than 11 claims). Additionally, we only included spending on drugs that appeared in IQVIA NSP, which was necessary to estimate provider acquisition costs.

While the final sample represented the majority of spending in the full target population, there were some cases where the sample did not contain any drug-level data for an entire stratum (i.e., unique combination of year, payer, provider type, 340B discount status, and HCPCS). Because the unsampled strata could differ systematically from the sampled strata, we identified a study population that was narrower than the full target population, which excluded the unsampled strata.

Specifically, the unsampled strata included HCPCS codes classified as miscellaneous (J7308-J7402, Q100-Q2028) or other (C8957-C9488) (American Academy of Professional Coders, n.d.). These miscellaneous drugs made up 43 percent (n=87) of the HCPCS codes with no sample data. In addition, 12 percent were vaccines (n=24 HCPCS codes), 9 percent were chemotherapy drugs (n=18), 8 percent were radiopharmaceuticals (n=17), 8 percent were clotting factors (n=16), 5 percent were stem cell therapies (n=10), and 4 percent were immunoglobulins (n=5). In general, these unsampled strata contained few claims and made up a very small fraction of total spending in the full target population. After excluding these unsampled strata, the study population covered 88 percent and 94 percent of the full target population of Medicare and Medicaid spending, respectively.

## A.3 Outlier Analysis and Exclusions

When aggregating utilization (i.e., quantity sold), spending, and prices from the Medicare claims data, we excluded claims with outlying sales prices, because the outliers may be typographical errors or may result from expressing the quantity of drug in the wrong unit. For the outlier analysis, we followed the same general procedure as CMS describes (Centers for Medicare & Medicaid Services, 2020-2022).^47^ While outlier claims were excluded when calculating NDC-level prices or spending for the sample, we included these outlier claims’ spending in the target and study populations since the reimbursement amount generally does not contain errors.

In addition to excluding specific claims with outlying prices, we also performed a separate outlier analysis on the final sample. We compared each drug’s net sales price to its net acquisition cost, at each available stage of the supply chain. We excluded extreme observations where the sales price was over 100 times the acquisition cost, or where the acquisition cost was over 100 times the sales price. Errors of this magnitude likely indicate errors in unit conversions and were rare.^48^ We similarly excluded cases where we identified inconsistencies or possible errors in the package information or HCPCS dosage in the CMS crosswalks.^49^

## A.4 Estimating Wholesaler Acquisition Costs from VA FSS Data

We estimated net wholesaler acquisition costs using VA FSS pricing data, which lists discounted prices on generic and brand drugs under various types of contracts, including Big Four price agreements, FSS price agreements, and national contract (NC) price agreements (U.S. Department of Veterans Affairs, Office of Procurement, Acquisition and Logistics, 2023). FSS prices are based on actual discounts given to direct purchasers, making them appropriate for estimating wholesalers’ actual net acquisition costs. NC contracts are also useful because they often reflect additional discounts that can be achieved in exchange for preferred placement on the VA’s national formulary (3 Axis Advisors, 2023). In the case of brand drugs, these additional discounts likely do not go to wholesalers, but rather to PBMs. For generic drugs, however, these additional discounts likely are accessible to wholesalers, at least in part, because wholesalers act as price setters in generic drug markets (Seeley, 2022) and can use the increased competition among generic manufacturers to negotiate lower prices. We therefore used the FSS and NC prices to estimate the net wholesaler acquisition cost of generic drugs, and we used only the FSS prices to estimate wholesalers’ net acquisition cost of brand drugs. We did not use Big Four prices because these stipulate additional statutory discounts, which may not reflect the actual negotiation processes between wholesalers and manufacturers.

We merged VA FSS pricing files for 2020, 2021, and 2022 with IQVIA NSP pricing data by 11-digit NDC and year and filtered to in-scope outpatient drugs that appear in either the CMS Medicare Part B HCPCS-NDC Crosswalk files (Centers for Medicare & Medicaid Services, 2020-2022) or the CMS MDRP drug list (Medicaid.gov, 2020-2022).^50^ For each in-scope, 11-digit NDC with data in both sources in a given year, we calculated (a) the weighted-average NSP price per extended unit in that year and (b) the simple average VA FSS price per extended unit across selected contract types in that year’s pricing file. We then computed the ratio of the average NSP price to the average VA FSS price. This comparison of the NSP price with the VA FSS price was made because every drug in our sample had an available NSP price. Additionally, we expect the NSP price and the VA FSS price to be correlated because the former estimates the wholesaler’s sales price (before the GPO fee), and the latter estimates the wholesaler’s net acquisition cost. The VA FSS-to-NSP price ratio therefore represents the wholesaler’s markup on the drug. Because of extreme outliers, we removed observations in the top and bottom five percent of the FSS-to-NSP price ratios. On average, this removed cases where the two prices differed by roughly a factor of 10. We removed these extreme outliers because the large discrepancy may be a result of the two datasets referring to different package sizes or not expressing the original prices on a per-package basis.

Many of the drugs in our final sample were not in the matched VA FSS-NSP dataset. We therefore developed a linear model to predict the average markup between the VA FSS price and the NSP price, so that we could calculate expected wholesaler net acquisition costs for all drugs in our sample. To develop the model, we conducted a stepwise model selection procedure that iteratively added and dropped terms and selected the best-fitting model with the lowest Akaike Information Criterion (AIC). To identify the optimal model, we performed this stepwise procedure with three different starting models, shown below. We compared the selected models across the three stepwise procedures and chose the one with the best fit (i.e., lowest AIC). The price terms (p_NSP_, p_FSS_, and p_WAC_) all refer to prices per extended unit. We included the NSP price and the WAC price as predictors because discounts and drug prices are correlated, at least in the case of manufacturer net prices (Sood, et al., 2020). t is a numeric variable for the calendar year. I_generic_ is an indicator variable that takes the value of one (1) if the drug is a brand and zero (0) if the drug is a generic. We included all interaction terms with the generic drug indicator variable because price discounts are expected to differ for brands versus generics.

log ((NSP)/(FSS)) = (β_0_ + β_1_ t + β_2_ p_NSP_ + β_3_ p_WAC_) + I_generic_ (β_4_ + β_5_ t + β_6_ p_NSP_ + β_7_ p_WAC_) Equation A-1: The logarithm of NSP divided by FSS equals beta subscript 0 plus beta subscript 1 times t plus beta subscript 2 times p subscript NSP plus beta subscript 3 times p subscript WAC, plus I subscript generic times the quantity beta subscript 4 plus beta subscript 5 times t plus beta subscript 6 times p subscript NSP plus beta subscript 7 times p subscript WAC. (A-1)

log ((NSP)/(FSS)) = (β_0_ + β_1_ t + β_2_ log p_NSP_ + β_3_ log p_WAC_) + I_generic_ (β_4_ + β_5_ t + β_6_ log p_NSP_ + β_7_ log p_WAC_) Equation A-2: The logarithm of NSP divided by FSS equals beta subscript 0 plus beta subscript 1 times t plus beta subscript 2 times the logarithm of p subscript NSP plus beta subscript 3 times the logarithm of p subscript WAC, plus I subscript generic times the quantity beta subscript 4 plus beta subscript 5 times t plus beta subscript 6 times the logarithm of p subscript NSP plus beta subscript 7 times the logarithm of p subscript WAC. (A-2)

log ((NSP)/(FSS)) = (β_0_ + β_1_ t + β_2_ log ((p_NSP_)/(p_WAC_))) + I_generic_ (β_3_ + β_4_ t + β_5_ log ((p_NSP_)/(p_WAC_))) Equation A-3: The logarithm of NSP divided by FSS equals beta subscript 0 plus beta subscript 1 times t plus beta subscript 2 times the logarithm of p subscript NSP divided by p subscript WAC, plus I subscript generic times the quantity beta subscript 3 plus beta subscript 4 times t plus beta subscript 5 times the logarithm of p subscript NSP divided by p subscript WAC. (A-3)

The final model we selected is shown below in equation A-4. Table A-1 shows the model coefficients, standard errors, and p values.

log ((NSP)/(FSS)) = β_0_ + β_1_ t + (β_2_ log p_NSP_ + β_3_ log p_WAC_) + I_generic_ (β_4_ + β_5_ log p_NSP_ + β_6_ log p_WAC_) Equation A-4: The logarithm of NSP divided by FSS equals beta subscript 0 plus beta subscript 1 times t plus the quantity beta subscript 2 times the logarithm of p subscript NSP plus beta subscript 3 times the logarithm of p subscript WAC, plus I subscript generic times the quantity beta subscript 4 plus beta subscript 5 times the logarithm of p subscript NSP plus beta subscript 6 times the logarithm of p subscript WAC. (A-4)

Table A-1 Selected Model for Predicting the NSP-to-FSS Price Discount

Variable | Coefficient | Point Estimate | Standard Error | p Value
Intercept | β _0_ | 25.4736 | 11.3790 | 0.0252
t | β _1_ | −0.0124 | 0.0056 | 0.0272
log p_NSP_ | β _2_ | 0.0185 | 0.0172 | 0.2840
log p_WAC_ | β _3_ | −0.0597 | 0.0177 | 0.0008
I _generic_ | β _4_ | −0.0856 | 0.0170 | <0.0001
I_generic_ · log p_NSP_ | β _5_ | 0.1535 | 0.0238 | <0.0001
I_generic_ · log p_WAC_ | β _6_ | −0.1268 | 0.0238 | <0.0001

Using the model of equation A-4, we calculated the expected VA FSS-to-NSP ratio (i.e., the reciprocal of the model output) for each 11-digit NDC in our merged VA FSS-NSP sample. To avoid overfitting or poor fits due to extrapolation when applying the model to new drugs, we binned the predicted VA FSS-to-NSP ratios into four groups based on quartiles and computed the mean ratio for each drug group. These drug groups and mean predicted ratios are shown in Table A-2. We performed this binning procedure separately for brands and generics.

Table A-2 Drug Groups for Predicting VA FSS-to-NSP Price Ratio

Brand Status | Range of Predicted VA FSS-to-NSP Price Ratio | Mean VA FSS-to-NSP Price Ratio | Number of 11-digit NDCs in Sample
Brand | Less than 0.768 | 0.718 | 387
Brand | 0.768 to 0.846 | 0.807 | 393
Brand | 0.846 to 0.937 | 0.892 | 418
Brand | Greater than 0.937 | 0.997 | 387
Generic | Less than 0.812 | 0.784 | 372
Generic | 0.812 to 0.860 | 0.835 | 465
Generic | 0.860 to 0.919 | 0.887 | 458
Generic | Greater than 0.919 | 0.991 | 398

For each 11-digit NDC in our drug sample, we used the fitted model of equation A-4 to calculate the expected VA FSS-to-NSP ratio and then assigned the mean ratio of Table A-2 based on the drug’s price group. Multiplying this ratio by the NSP price yielded the estimate of the wholesaler’s net acquisition cost on non-340B-discounted drugs. As with other price metrics, to collapse from 11-digit NDC to 9-digit NDC, we divided total dollar sales, expressed in terms of the wholesaler’s net acquisition cost, by the total extended units sold across all package sizes in the year.

46 These files were accessible through a CMS Innovator Data Use Agreement (DUA #54757) with Dobson | DaVanzo.

47 Specifically, we grouped outliers by year, HCPCS code, and provider type (either outpatient setting or physician office) and calculated lower and upper bounds of the provider sales price per HCPCS dosage unit as (25^th^ percentile) – 1.5×(interquartile range) and (75^th^ percentile) + 1.5×(interquartile range), respectively. Claims with a provider sales price per HCPCS dosage unit outside of these bounds were excluded from the drug claims sample.

48 This exclusion reduced the sample by only $1.6 billion, or 3.8 percent.

49 Drugs with multiple dosage units reported for a single HCPCS in a given year, or multiple billing units per package reported for a single NDC-11 in a given year, were excluded from the sample.

50 To access historical versions of the VA FSS pricing file, we used the Internet Archive (Internet Archive, 2024). For each year in the study period, only one archive of the VA FSS pricing file was available, which we used as representative of the prices for the full year.