# ABBREVIATIONS

Abbreviation: Definition
AIC: Akaike Information Criterion
AMP: Average manufacturer price
ASPE: Assistant Secretary for Planning and Evaluation, HHS
AWP: Average Wholesale Price
CI: Confidence Interval
CMS: U.S. Centers for Medicare & Medicaid Services
CPI: Consumer Price Index
FDA: U.S. Food & Drug Administration
FFS: Fee-for-Service
FSS: Federal Supply Schedule Service
GAO: U.S. Government Accountability Office
GPO: Group Purchasing Organization
HCPCS: Healthcare Common Procedure Coding System
HHS: U.S. Department of Health & Human Services
MAC: Medicare Administrative Contractor
MCO: Managed Care Organization
MDRP: Medicaid Drug Rebate Program
NDC: National Drug Code
NSP: National Sales Perspective
OIG: U.S. Office of Inspector General, HHS
OPPS: Outpatient Prospective Payment System
PBM: Pharmacy Benefit Manager
SDP: Office of Science and Data Policy, ASPE HHS
TOS: Type of Service
URA: Unit Rebate Amount
WAC: Wholesale Acquisition Cost