# References

1 Nelson, C., N. Lurie, J. Wasserman, and S. Zakowski. “Conceptualizing and Defining Public Health Emergency Preparedness.” American Journal of Public Health, vol. 97, April 1, 2007, pp. S9–S11. 10.2105/AJPH.2007.114496.17413078
2 Administration for Strategic Preparedness and Response. “ASPR TRACIE Evaluation of Hazard Vulnerability Assessment Tools.” January 2024. https://files.asprtracie.hhs.gov/documents/aspr-tracie-evaluation-of-hva-tools-3–10-17.pdf. Accessed May 6, 2024.
3 Federal Emergency Management Agency. “Mission Areas and Core Capabilities.” July 2020. https://www.fema.gov/emergency-managers/national-preparedness/mission-core-capabilities. Accessed June 17, 2024.
4 Federal Emergency Management Agency. “National Preparedness Goal.” March 2023. https://www.fema.gov/emergency-managers/national-preparedness/goal. Accessed May 6, 2024.
5 Assistant Secretary for Preparedness and Response. “Hospital Preparedness Program.” n.d. https://aspr.hhs.gov/HealthCareReadiness/HPP/Documents/HPP%20Fact%20Sheet%20April%202021.pdf.Accessed May 6, 2024.
6 Centers for Disease Control and Prevention. “2023 Readiness Report.” 2023. https://www.cdc.gov/orr/media/pdfs/ORR_2023_Readiness_Report_508.pdf. Accessed June 17, 2024.
7 Federal Emergency Management Agency. “Preparedness Grants.” February 2024. https://www.fema.gov/grants/preparedness. Accessed June 17, 2024.
8 World Health Organization. “Key Approaches to Strengthening Emergency Preparedness and Response.” n.d. https://www.who.int/europe/emergencies/our-work-in-emergencies/key-approaches. Accessed June 17, 2024.
9 Federal Emergency Management Agency. “2019 National Threat and Hazard Identification and Risk Assessment (THIRA): Overview and Methodology.” U.S. Department of Homeland Security, July 2019. https://www.fema.gov/sites/default/files/2020-06/fema_national-thira-overview-methodology_2019_0.pdf. Accessed May 6, 2024.
10 Centers for Disease Control and Prevention. “Division of State and Local Readiness Friday Update.” June 2024. https://www.cdc.gov/readiness/media/pdfs/2024/06/2024-06-07_DSLR-Friday-Update_508C.pdf.
11 Centers for Medicare & Medicaid Services. “Core EP Rule Elements.” September 2023. https://www.cms.gov/medicare/health-safety-standards/quality-safety-oversight-emergency-preparedness/core-ep-rule-elements. Accessed June 13, 2024.
12 Centers for Disease Control and Prevention. “Public Health Emergency Preparedness and Response Capabilities: National Standards for State, Local, Tribal, and Territorial Public Health.” October 2018. https://www.cdc.gov/readiness/media/pdfs/CDC_PreparednesResponseCapabilities_October2018_Final_508.pdf.
13 Administration for Strategic Preparedness and Response. “General Overview of Healthcare Coalitions.” n.d. https://files.asprtracie.hhs.gov/documents/aspr-tracie-general-overview-hccs.pdf.
14 Stoto, M., and C. Nelson. “Measuring and Assessing Public Health Emergency Preparedness: A Methodological Primer.” SSRN, September 2012. 10.2139/ssrn.2886349.
15 Asch, S.M., M. Stoto, M. Mendes, R. Burciaga Valdez, M.E. Gallagher, P. Halverson, and N. Lurie. “A Review of Instruments Assessing Public Health Preparedness.” Public Health Reports, vol. 120, no. 5, October 2005, pp. 532– 542. 10.1177/003335490512000508.16224986
16 Nelson, C., N. Lurie, J. Wasserman, and S. Zakowski. “Conceptualizing and Defining Public Health Emergency Preparedness.” American Journal of Public Health, vol. 97, April 1, 2007, pp. S9–S11. 10.2105/AJPH.2007.114496.17413078
17 Stoto, M., and C. Nelson. “Measuring and Assessing Public Health Emergency Preparedness: A Methodological Primer.” SSRN, August 2023. 10.2139/ssrn.4538548.
18 Ibid.
19 Piltch-Loeb, R.N., C. Nelson, J. Kraemer, E. Savoia, and M. Stoto. “A Peer Assessment Approach for Learning from Public Health Emergencies.” Public Health Reports, vol. 129, no. 6, November 2014, pp. 28–34. 10.1177/00333549141296S405.25355972
20 Ghosh, J.K., B. Martinez, C. Beck, and C. Rogers. “Community Outbreak Preparedness Index (COPI).” Heluna Health, October 2023. COPI_Technical_Report_October_2023.pdf.
21 Marcozzi, D.E., R. Pietrobon, J.V. Lawler, M.T. French, C. Mecher, J. Peffer, N.E. Baehr, “Development of a Hospital Medical Surge Preparedness Index Using a National Hospital Survey.” Health Service and Outcomes Research Methodology, vol. 20, no. 1, 2020, pp. 60–83.
22 Administration for Strategic Preparedness and Response. “2019–2023 Hospital Preparedness Program: Performance Measures Implementation Guidance.” 2022. https://aspr.hhs.gov/HealthCareReadiness/guidance/Documents/2019-2023-HPP-Performance-Measures-Implementation-Guidance-8Nov22.pdf.
23 Lumpkin, J.R., Y.K. Miller, T. Inglesby, J.M. Links, A.T. Schwartz, C.C. Slemp, R.L. Burhans, J. Blumenstock, and A.S. Khan. “The Importance of Establishing a National Health Security Preparedness Index.” Biosecurity and Bioterrorism: Biodefense Strategy, Practice, and Science, vol. 11, no. 1, 2013, pp. 81–87.23506403
24 McKillop, M., R. Faberman, and D. Alpert Lieberman. “Ready or Not 2024: Protecting the Public’s Health from Diseases, Disasters, and Bioterrorism.” Trust for America’s Health, 2024. https://www.tfah.org/report-details/ready-or-not-2024/.
25 Glik, D.C., D.P. Eisenman, I. Donatello, A. Afifi, M. Stajura, M.L. Prelip, J. Sammartinova, “Reliability and Validity of the Assessment for Disaster Engagement with Partners Tool (ADEPT) for Local Health Departments.” Public Health Reports, vol. 129, no. 6, suppl. 4, 2014, pp. 77–86. 10.1177/00333549141296S411.25355978
26 Dorn, B.C., E. Savoia, M.A. Testa, M.A. Stoto, and L.J. Marcus. “Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance.” Public Health Reports, vol. 122, no. 3, 2007, pp. 329–38. doi: 10.1177/003335490712200306. PMID: 17518304; PMCID: PMC1847495. Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance - PMC (nih.gov).17518304
27 Davis, Mary, Glen Mays, James Bellamy, Christine Bevc, and Cammie Marti. “Improving Public Health Preparedness Capacity Measurement: Development of the Local Health Department Preparedness Capacities Assessment Survey.” Disaster Medicine and Public Health Preparedness, vol 7, 2013, pp. 1–7. 10.1017/dmp.2013.108.24618135
28 Boyce, M.R., and R. Katz. “Rapid Urban Health Security Assessment Tool: A New Resource for Evaluating Local-Level Public Health Preparedness.” BMJ Global Health, vol. 5, no. 6, 2020, article e002606.
29 Oppenheim, B., M. Gallivan, N.K. Madhav, N. Brown, V. Serhiyenko, N.D. Wolfe, and P. Ayscue. “Assessing Global Preparedness for the Next Pandemic: Development and Application of an Epidemic Preparedness Index.” BMJ Global Health, vol. 4, no. 1, 2019, article e001157.
30 Global Health Security Index. “What is the GHS Index?” n.d. https://ghsindex.org/about/#:~:text=The%20Global%20Health%20Security%20%28GHS%29%20Index%20is%20an,prevent%2C%20detect%2C%20and%20respond%20to%20epidemics%20and%20pandemics.
31 Pan American Health Organization. “Preparedness Index for Health Emergencies and Disasters.” 2019. https://www.paho.org/en/documents/preparedness-index-health-emergencies-and-disasters-0.
32 Gupta, V., J.D. Kraemer, R. Katz, A.K. Jha, V.B. Kerry, J. Sane, J. Ollgren, “Analysis of Results from the Joint External Evaluation: Examining Its Strength and Assessing for Trends Among Participating Countries.” Journal of Global Health, vol. 8, no. 2, 2018.
33 Stribling, J., A. Clifton, G. McGill, and K. de Vries. “Examining the UK Covid-19 Mortality Paradox: Pandemic Preparedness, Healthcare Expenditure, and the Nursing Workforce.” Journal of Advanced Nursing, vol. 76, no. 12, 2020, pp. 3218–3227. 10.1111/jan.14562.32914471
34 Kaiser, M.A., T.Y. Chen, and P. Gluckman. “Should Policy Makers Trust Composite Indices? A Commentary on the Pitfalls of Inappropriate Indices for Policy Formation.” Health Research Policy and Systems, vol. 19, no.1, March 2021. 10.1186/s12961-021-00702-4.
35 Haider, N., A. Yavlinsky, Y.M. Chang, M.N. Hasan, C. Benfield, A.Y. Osman, M.J. Uddin, “The Global Health Security Index and Joint External Evaluation Score for Health Preparedness Are Not Correlated with Countries' COVID-19 Detection Response Time and Mortality Outcome.” Epidemiology and Infection, vol. 148, 2020, article e210. 10.1017/S0950268820002046.32892793
36 Lumpkin, J.R., Y.K. Miller, T. Inglesby, J.M. Links, A.T. Schwartz, C.C. Slemp, R.L. Burhans, J. Blumenstock, and A.S. Khan. “The Importance of Establishing a National Health Security Preparedness Index.” Biosecurity and Bioterrorism: Biodefense Strategy, Practice, and Science, vol. 11, no. 1, 2013, pp. 81–87.23506403
37 Keim, M.E., and A.P. Lovallo. “Validity of the National Health Security Preparedness Index as a Predictor of Excess COVID-19 Mortality.” Prehospital and Disaster Medicine, vol. 36, no. 2, 2021, pp. 141–144. 10.1017/S1049023X20001521.33397547
38 Moulton, A.D. “A COVID-19 Lesson: Better Health Emergency Preparedness Standards Are Needed.” Health Security, vol. 20, no. 6, 2022, pp. 457–466. 10.1089/hs.2022.0037.36367989
39 Mays, G., and M. Childress. “2021 Release of National Health Security Preparedness Index.” University of Colorado, Colorado School of Public Health, June 2021.
40 National Health Security Preparedness Index. “Measures List: National Health Security Preparedness Index, 2021 Release.” https://nhspi.org/wp-content/uploads/2021/06/2021-NHSPI-Measure-List.pdf.
41 Federal Emergency Management Agency. “National Preparedness Goal.” U.S. Department of Homeland Security, September 2015. https://www.fema.gov/sites/default/files/2020-06/national_preparedness_goal_2nd_edition.pdf.
42 Centers for Disease Control and Prevention. “Public Health Emergency Preparedness and Response Capabilities: National Standards for State, Local, Tribal, and Territorial Public Health.” October 2018. https://www.cdc.gov/orr/readiness/00_docs/CDC_PreparednesResponseCapabilities_October2018_Final_508.pdf.
43 Assistant Secretary for Preparedness and Response. “2017–2022 Health Care Preparedness and Response Capabilities.” November 2016. https://www.phe.gov/Preparedness/planning/hpp/reports/Documents/2017-2022-healthcare-pr-capablities.pdf.
44 Federal Emergency Management Agency. “National Preparedness Goal.” U.S. Department of Homeland Security, September 2015. https://www.fema.gov/sites/default/files/2020-06/national_preparedness_goal_2nd_edition.pdf.
45 Centers for Disease Control and Prevention. “Public Health Emergency Preparedness and Response Capabilities: National Standards for State, Local, Tribal, and Territorial Public Health.” October 2018. https://www.cdc.gov/orr/readiness/00_docs/CDC_PreparednesResponseCapabilities_October2018_Final_508.pdf.
46 Assistant Secretary for Preparedness and Response. “2017–2022 Health Care Preparedness and Response Capabilities.” November 2016. https://www.phe.gov/Preparedness/planning/hpp/reports/Documents/2017-2022-healthcare-pr-capablities.pdf.
47 Stribling, J., A. Clifton, G. McGill, and K. de Vries. “Examining the UK Covid-19 Mortality Paradox: Pandemic Preparedness, Healthcare Expenditure, and the Nursing Workforce.” Journal of Advanced Nursing, vol. 76, no. 12, 2020, pp. 3218–3227. 10.1111/jan.14562.32914471
48 Kaiser, M.A., T.Y. Chen, and P. Gluckman. “Should Policy Makers Trust Composite Indices? A Commentary on the Pitfalls of Inappropriate Indices for Policy Formation.” Health Research Policy and Systems, vol. 19, no.1, March 2021. 10.1186/s12961-021-00702-4.
49 Keim, M.E., and A.P. Lovallo. “Validity of the National Health Security Preparedness Index as a Predictor of Excess COVID-19 Mortality.” Prehospital and Disaster Medicine, vol. 36, no. 2, 2021, pp. 141–144. 10.1017/S1049023X20001521.33397547
50 Haider, N., A. Yavlinsky, Y.M. Chang, M.N. Hasan, C. Benfield, A.Y. Osman, M.J. Uddin, “The Global Health Security Index and Joint External Evaluation Score for Health Preparedness Are Not Correlated with Countries' COVID-19 Detection Response Time and Mortality Outcome.” Epidemiology and Infection, vol. 148, 2020, article e210. 10.1017/S0950268820002046.32892793
51 Keim, M.E., and A.P. Lovallo. “Validity of the National Health Security Preparedness Index as a Predictor of Excess COVID-19 Mortality.” Prehospital and Disaster Medicine, vol. 36, no. 2, 2021, pp. 141–144. 10.1017/S1049023X20001521.33397547
52 Moulton, A.D. “A COVID-19 Lesson: Better Health Emergency Preparedness Standards Are Needed.” Health Security, vol. 20, no. 6, 2022, pp. 457–466. 10.1089/hs.2022.0037.36367989
53 Mays, G., and M. Childress. “2021 Release of National Health Security Preparedness Index.” University of Colorado, Colorado School of Public Health, June 2021.
54 Nelson, C., N. Lurie, J. Wasserman. “Assessing public health emergency preparedness: concepts, tools, and challenges.” Annual Rev. Public Health, vol. 28, 2007, pp. 1– 18. 10.1146/annurev.publhealth.28.021406.144054.17129174
55 National Health Security Preparedness Index. “Measures List: National Health Security Preparedness Index, 2021 Release” 2021. https://nhspi.org/wp-content/uploads/2021/06/2021-NHSPI-Measure-List.pdf.
56 McKillop, M., R. Faberman, and D. Alpert Lieberman. “Ready or Not 2024: Protecting the Public’s Health from Diseases, Disasters, and Bioterrorism.” Trust for America’s Health, 2024. https://www.tfah.org/report-details/ready-or-not-2024/.
57 Ghosh, J.K., B. Martinez, C. Beck, and C. Rogers. “Community Outbreak Preparedness Index (COPI).” Heluna Health, October 2023. COPI_Technical_Report_October_2023.pdf.
58 U.S. Department of Health and Human Services. “HPP Performance Metrics – FY 2021 Dashboard.” 2021. https://dhhs.maps.arcgis.com/apps/dashboards/71b5f53173cb4f4e9248b85244158151.
59 Dorn, B.C., E. Savoia, M.A. Testa, M.A. Stoto, and L.J. Marcus. “Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance.” Public Health Reports, vol. 122, no. 3, 2007, pp. 329–38. doi: 10.1177/003335490712200306. PMID: 17518304; PMCID: PMC1847495. Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance - PMC (nih.gov).17518304
60 Davis, Mary, Glen Mays, James Bellamy, Christine Bevc, and Cammie Marti. “Improving Public Health Preparedness Capacity Measurement: Development of the Local Health Department Preparedness Capacities Assessment Survey.” Disaster Medicine and Public Health Preparedness, vol 7, 2013, pp. 1–7. 10.1017/dmp.2013.108.24618135
61 Boyce, M.R., and R. Katz. “Rapid Urban Health Security Assessment Tool: A New Resource for Evaluating Local-Level Public Health Preparedness.” BMJ Global Health, vol. 5, no. 6, 2020, article e002606.
62 Glik, D.C., D.P. Eisenman, I. Donatello, A. Afifi, M. Stajura, M.L. Prelip, J. Sammartinova, “Reliability and Validity of the Assessment for Disaster Engagement with Partners Tool (ADEPT) for Local Health Departments.” Public Health Reports, vol. 129, no. 6, suppl. 4, 2014, pp. 77–86. 10.1177/00333549141296S411.25355978
63 National Health Security Preparedness Index. “Methodology for the 2021 Release of the National Health Security Preparedness Index.” https://nhspi.org/wp-content/uploads/2021/NHSPI_2021_Methodology.pdf.
64 McKillop, M., R. Faberman, and D. Alpert Lieberman. “Ready or Not 2024: Protecting the Public’s Health from Diseases, Disasters, and Bioterrorism.” Trust for America’s Health, 2024. https://www.tfah.org/report-details/ready-or-not-2024/.
65 Ghosh, J.K., B. Martinez, C. Beck, and C. Rogers. “Community Outbreak Preparedness Index (COPI).” Heluna Health, October 2023. COPI_Technical_Report_October_2023.pdf.
66 Marcozzi, D.E., R. Pietrobon, J.V. Lawler, M.T. French, C. Mecher, J. Peffer, N.E. Baehr, “Development of a Hospital Medical Surge Preparedness Index Using a National Hospital Survey.” Health Service and Outcomes Research Methodology, vol. 20, no. 1, 2020, pp. 60–83.
67 National Health Security Preparedness Index. “Measures List: National Health Security Preparedness Index, 2021 Release.” https://nhspi.org/wp-content/uploads/2021/06/2021-NHSPI-Measure-List.pdf.
68 Ghosh, J.K., B. Martinez, C. Beck, and C. Rogers. “Community Outbreak Preparedness Index (COPI).” Heluna Health, October 2023. COPI_Technical_Report_October_2023.pdf.
69 Gray, B., J. Eaton, J. Christy, J. Duncan, F. Hanna, and S. Kasi. “A Proactive Approach: Examples for Integrating Disaster Risk Reduction and Mental Health and Psychosocial Support Programming.” International Journal of Disaster Risk Reduction, vol. 15, no. 54, 2021. 10.1016/j.ijdrr.2021.102051.
70 Cutter, S., C. Burton, and C.T. Emrich. "Disaster Resilience Indicators for Benchmarking Baseline Conditions.” Journal of Homeland Security and Emergency Management, vol. 7: no. 1, August 2010. 10.2202/1547-7355.1732.
71 Peacock, W.G., S.D. Brody, W.A. Seitz, W.J. Merrell, A. Vedlitz, S. Zahran, R.C. Harriss, “Advancing Resilience of Coastal Localities: Developing, Implementing, and Sustaining the Use of Coastal Resilience Indicators: A Final Report.” Hazard Reduction & Recovery Center, 2010, pp. 1–148.
72 United States Census Bureau. 2020. Community Resilience Estimates: Quick Guide. Also available at https://www2.census.gov/data/experimental-data-products/community-resilience-estimates/2020/technical-document.pdf.
73 Sherrieb, K., F.H. Norris, and S. Galea. “Measuring Capacities for Community Resilience.” Social Indicators Research, vol. 99, no. 2, 2010, pp. 227–247.
74 Surgo Ventures. “COVID-19 Community Vulnerability Index (CCVI) Methodology.” 2020. https://covid-static-assets.s3.amazonaws.com/US-CCVI/COVID-19+Community+Vulnerability+Index+(CCVI)+Methodology.pdf.
75 Tiwari, A., A.V. Dadhania, V.A.B. Ragunathrao, and E.R. A Oliveira. “Using Machine Learning to Develop a Novel COVID-19 Vulnerability Index (C19VI).” Science of the Total Environment, vol. 773, 2021, article 14565.
76 Marvel, S.W., J.S. House, M. Wheeler, K. Song, Y.H. Zhou, F.A. Wright, W.A. Chiu, “The COVID-19 Pandemic Vulnerability Index (PVI) Dashboard: Monitoring County-Level Vulnerability Using Visualization, Statistical Modeling, and Machine Learning.” Environmental Health Perspectives, vol. 129, no. 1, 2021.
77 Flanagan, B.E., E.W. Gregory, E.J. Hallisey, J.L. Heitgerd, and B. Lewis. “A Social Vulnerability Index for Disaster Management.” Journal of Homeland Security and Emergency Management, vol. 8, no. 1, 2011.
78 Rogers, C.J., B. Cutler, K. Bhamidipati, and J.K. Ghosh. “Preparing for the Next Outbreak: A Review of Indices Measuring Outbreak Preparedness, Vulnerability, and Resilience.” Preventive Medicine Reports, vol. 35, 2023, article 102282. 10.1016/j.pmedr.2023.102282.37333424
79 Office of Disease Prevention and Health Promotion, U.S. Department of Health and Human Services. “Federal Plan for Equitable Long-Term Recovery and Resilience for Social, Behavioral, and Community Health.” January 2022. Available at: https://health.gov/our-work/national-health-initiatives/equitable-long-term-recovery-and-resilience
80 Boyce, M. “State-level public health preparedness indices as predictors of COVID-19 mortality outcomes: results from the United States of America in 2020.” Frontiers in Epidemiology, December 2023. DOI: 10.3389/fepid.2023.1229718.
81 Stoto, M., and C. Nelson. “Measuring and Assessing Public Health Emergency Preparedness: A Methodological Primer.” SSRN, August 2023. 10.2139/ssrn.4538548.
82 Ghosh, J.K., B. Martinez, C. Beck, and C. Rogers. “Community Outbreak Preparedness Index (COPI).” Heluna Health, October 2023. COPI_Technical_Report_October_2023.pdf.
83 Environmental Protection Agency (EPA). “Community Health Vulnerability Index.”. July 2017. https://www.epa.gov/sites/default/files/2017-07/documents/community_health_vulnerability_index.pdf.
84 Nallen, Joe. “ReadyMapper: A Digital Solution to Optimize Health System Resilience and Response During Wildfires.” Crisis Ready, 2022. https://www.crisisready.io/optimizing-health-response-during-wild-fires-with-real-time-integrated-data/.
85 National Weather Service. “TsunamiReady Guidelines.”n.d. https://www.weather.gov/tsunamiready/guidelines.
86 Hammer, J., D.G. Ruggieri, C. Thomas, and J. Caum. “Local Extreme Heat Planning: An Interactive Tool to Examine a Heat Vulnerability Index for Philadelphia, Pennsylvania.” Journal of Urban Health, vol. 97, no. 4, 2020, pp. 519–528. 10.1007/s11524-020-00443-9.32495120
87 Moore, M., B. Gelfeld, and C.P. Adeyemi Okunogbe. “Identifying Future Disease Hot Spots: Infectious Disease Vulnerability Index.” Rand Health Quarterly, vol. 6, no. 3, 2017.
88 Lee, J.M., R. Jansen, K.E. Sanderson, F. Guerra, S. Keller-Olaman, M. Murti, T.L. O'Sullivan, “Public Health Emergency Preparedness for Infectious Disease Emergencies: A Scoping Review of Recent Evidence.” BMC Public Health, vol. 23, no. 1, 2023, pp. 420. 10.1186/s12889-023-15313-7.36864415
89 Nallen, Joe. “ReadyMapper: A Digital Solution to Optimize Health System Resilience and Response During Wildfires.” Crisis Ready, 2022. https://www.crisisready.io/optimizing-health-response-during-wild-fires-with-real-time-integrated-data/.
90 National Health Security Preparedness Index. “Measures List: National Health Security Preparedness Index, 2021 Release.” https://nhspi.org/wp-content/uploads/2021/06/2021-NHSPI-Measure-List.pdf.
91 Ghosh, J.K., B. Martinez, C. Beck, and C. Rogers. “Community Outbreak Preparedness Index (COPI).” Heluna Health, October 2023. COPI_Technical_Report_October_2023.pdf.
92 Glik, D.C., D.P. Eisenman, I. Donatello, A. Afifi, M. Stajura, M.L. Prelip, J. Sammartinova, “Reliability and Validity of the Assessment for Disaster Engagement with Partners Tool (ADEPT) for Local Health Departments.” Public Health Reports, vol. 129, no. 6, suppl. 4, 2014, pp. 77–86. 10.1177/00333549141296S411.25355978
93 Dorn, B.C., E. Savoia, M.A. Testa, M.A. Stoto, and L.J. Marcus. “Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance.” Public Health Reports, vol. 122, no. 3, 2007, pp. 329–38. doi: 10.1177/003335490712200306. PMID: 17518304; PMCID: PMC1847495. Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance - PMC (nih.gov).17518304
94 Boyce, M.R., and R. Katz. “Rapid Urban Health Security Assessment Tool: A New Resource for Evaluating Local-Level Public Health Preparedness.” BMJ Global Health, vol. 5, no. 6, 2020, article e002606.
95 Centers for Disease Control and Prevention. “Public Health Emergency Preparedness and Response Capabilities: National Standards for State, Local, Tribal, and Territorial Public Health.” October 2018. https://www.cdc.gov/orr/readiness/00_docs/CDC_PreparednesResponseCapabilities_October2018_Final_508.pdf.
96 Assistant Secretary for Preparedness and Response. “2017–2022 Health Care Preparedness and Response Capabilities.” November 2016. https://www.phe.gov/Preparedness/planning/hpp/reports/Documents/2017-2022-healthcare-pr-capablities.pdf.
97 Federal Emergency Management Agency. “National Preparedness Goal.” U.S. Department of Homeland Security, September 2015. https://www.fema.gov/sites/default/files/2020-06/national_preparedness_goal_2nd_edition.pdf.
98 Dorn, B.C., E. Savoia, M.A. Testa, M.A. Stoto, and L.J. Marcus. “Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance.” Public Health Reports, vol. 122, no. 3, 2007, pp. 329–38. doi: 10.1177/003335490712200306. PMID: 17518304; PMCID: PMC1847495. Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance - PMC (nih.gov).17518304
99 Ghosh, J.K., B. Martinez, C. Beck, and C. Rogers. “Community Outbreak Preparedness Index (COPI).” Heluna Health, October 2023. COPI_Technical_Report_October_2023.pdf.
100 Acosta, J.D., L. Burgette, A. Chandra, D.P. Eisenman, I. Gonzalez, D. Varda, and L. Xenakis. “How Community and Public Health Partnerships Contribute to Disaster Recovery and Resilience.” Disaster Medicine and Public Health Preparedness, vol. 12, no. 5, 2018, pp. 635–643. 10.1017/dmp.2017.130.29388518
101 Adams, R.M., M.L. Prelip, D.C. Glik, I. Donatello, and D.P. Eisenman. “Facilitating Partnerships with Community- and Faith-Based Organizations for Disaster Preparedness and Response: Results of a National Survey of Public Health Departments.” Disaster Medicine and Public Health Preparedness, vol. 12, no. 1, 2018, pp. 57–66. 10.1017/dmp.2017.3.28735594
102 Brewer, L.C., G. Asiedu, C. Jones, M. Richard, J. Erickson, J. Weis, A. Abbenyi, “Emergency Preparedness and Risk Communication Among African American Churches: Leveraging a Community-Based Participatory Research Partnership COVID-19 Initiative.” Preventing Chronic Disease, vol. 17, 2020. 10.5888/pcd17.200408.
103 Glik, D.C., D.P. Eisenman, I. Donatello, A. Afifi, M. Stajura, M.L. Prelip, J. Sammartinova, “Reliability and Validity of the Assessment for Disaster Engagement with Partners Tool (ADEPT) for Local Health Departments.” Public Health Reports, vol. 129, no. 6, suppl. 4, 2014, pp. 77–86. 10.1177/00333549141296S411.25355978
104 Marcozzi, D.E., R. Pietrobon, J.V. Lawler, M.T. French, C. Mecher, J. Peffer, N.E. Baehr, “Development of a Hospital Medical Surge Preparedness Index Using a National Hospital Survey.” Health Service and Outcomes Research Methodology, vol. 20, no. 1, 2020, pp. 60–83.
105 Administration for Strategic Preparedness and Response. “2019–2023 Hospital Preparedness Program: Performance Measures Implementation Guidance.” 2022. https://aspr.hhs.gov/HealthCareReadiness/guidance/Documents/2019-2023-HPP-Performance-Measures-Implementation-Guidance-8Nov22.pdf.
106 National Association of County and City Health Officials. “Administrative Preparedness: Emergency Reporting Practices for Health Departments.” September 2013. https://www.naccho.org/uploads/header-images/publichealth-preparedness/Admin-Prep_Reporting.pdf.
107 Centers for Disease Control and Prevention. “Public Health Emergency Preparedness and Response Capabilities: National Standards for State, Local, Tribal, and Territorial Public Health.” October 2018. https://www.cdc.gov/orr/readiness/00_docs/CDC_PreparednesResponseCapabilities_October2018_Final_508.pdf.
108 Gupta, N., S.A. Balcom, A. Gulliver, and R.L. Witherspoon. “Health Workforce Surge Capacity During the COVID-19 Pandemic and Other Global Respiratory Disease Outbreaks: A Systematic Review of Health System Requirements and Responses.” The International Journal of Health Planning and Management, vol. 36, no. 1, 2021, pp. 26–41. 10.1002/hpm.3137.
109 Stoto, M., and C. Nelson. “Measuring and Assessing Public Health Emergency Preparedness: A Methodological Primer.” SSRN, August 2023. 10.2139/ssrn.4538548.
110 Moulton, A.D. “A COVID-19 Lesson: Better Health Emergency Preparedness Standards Are Needed.” Health Security, vol. 20, no. 6, 2022, pp. 457–466. 10.1089/hs.2022.0037.36367989
111 Krieger, Nancy, Christian Testa, Jarvis T. Chen, William P. Hanage, and Alecia J. McGregor. “Relationship of Political Ideology of U.S. Federal and State Elected Officials and Key COVID Pandemic Outcomes Following Vaccine Rollout to Adults: April 2021–March 2022.” The Lancet Regional Health - Americas, vol. 16, 2022, article 100384. 10.1016/j.lana.2022.100384.36338898
112 Pence, J., I. Miller, T. Sakurahara, J. Whitacre, S. Reihani, E. Kee, and Z. Mohaghegh. “GIS-Based Integration of Social Vulnerability and Level 3 Probabilistic Risk Assessment to Advance Emergency Preparedness, Planning, and Response for Severe Nuclear Power Plant Accidents.” Risk Analysis, vol. 39, no. 6, 2019, pp. 1262–1280. 10.1111/risa.13241.30468695
113 Boyce, M. “State-level public health preparedness indices as predictors of COVID-19 mortality outcomes: results from the United States of America in 2020.” Frontiers in Epidemiology, December 2023. DOI: 10.3389/fepid.2023.1229718.
114 Stoto, M., and C. Nelson. “Measuring and Assessing Public Health Emergency Preparedness: A Methodological Primer.” SSRN, August 2023. 10.2139/ssrn.4538548.
115 Grimmelikhuijsen, S & E. Knies. “Validating a scale for citizen trust in government organizations.” International Review of Administrative Sciences, vol 83, no. 3, 2017, pp. 583 – 601. 10.1177/0020852315585950
116 Burns, K, P. Brown, M. Calnan, P.R. Ward, J. Little “Development and validation of the Trust in Government measure (TGM)”. BMC Public Health, 2023. 10.1186/s12889-023-16974-0
117 Pew Research Center. “Public Trust in Government: 1958 – 2024”. June 2024.https://www.pewresearch.org/politics/2024/06/24/public-trust-in-government-1958-2024/
118 SteelFisher, G., M. G. Finding, H.C. Caporello, K.M. Lubell, “Trust in U.S. Federal, State, and Local Public Health Agencies During COVID-19: Responses and Policy Implications.” Health Affairs, vol 42, no. 3, March 2023, pp. 328 – 337. 10.1377/hlthaff.2022.01204 36877902
119 Ghosh, J.K., B. Martinez, C. Beck, and C. Rogers. “Community Outbreak Preparedness Index (COPI).” Heluna Health, October 2023. COPI_Technical_Report_October_2023.pdf.
120 Federal Emergency Management Agency. “Pre-Disaster Recovery Planning Guide for Tribal Governments (FP 104–008-02).” U.S. Department of Homeland Security, September 2019. https://www.fema.gov/sites/default/files/2020-07/pre-disaster-recovery-planning-guide-for-tribal-government.pdf.
121 Federal Emergency Management Agency. “2022–2026 FEMA National Tribal Strategy.” U.S. Department of Homeland Security, 2022. https://www.fema.gov/sites/default/files/documents/fema_national-tribal-strategy_08182022.pdf.
122 Lorenzoni, Nina, Stephanie Kainrath, Maria Unterholzner, and Harold Stummer. "Instruments for Disaster Preparedness Evaluation: A Scoping Review." Australian Journal of Emergency Management, vol. 37, no. 3, 2022, pp. 56.
123 Moulton, A.D. “A COVID-19 Lesson: Better Health Emergency Preparedness Standards Are Needed.” Health Security, vol. 20, no. 6, 2022, pp. 457–466. 10.1089/hs.2022.0037.36367989
124 Keim, M.E., and A.P. Lovallo. “Validity of the National Health Security Preparedness Index as a Predictor of Excess COVID-19 Mortality.” Prehospital and Disaster Medicine, vol. 36, no. 2, 2021, pp. 141–144. 10.1017/S1049023X20001521.33397547
125 Kachali, Hlekiwe, Ira Haavisto, Riikka-Leena Leskelä, Auri Väljä, and Mikko Nuutinen. “Are Preparedness Indices Reflective of Pandemic Preparedness? A COVID-19 Reality Check.” International Journal of Disaster Risk Reduction, vol. 77, 2022, pp. 2212–4209. 10.1016/j.ijdrr.2022.103074.
126 NACCHOO, “2022 Preparedness Profile Study.” 2023. https://www.naccho.org/uploads/downloadable-resources/2022PrepProfile-PREVIEWREPORT.pdf.
127 National Health Security Preparedness Index. “Measures List: National Health Security Preparedness Index, 2021 Release.” 2021. https://nhspi.org/wp-content/uploads/2021/06/2021-NHSPI-Measure-List.pdf.
128 The White House. “National Cybersecurity Strategy.” March 2023. https://www.whitehouse.gov/wp-content/uploads/2023/03/National-Cybersecurity-Strategy-2023.pdf.
129 National Association of County and City Health Officials. “Hurricane and Flooding Preparedness Resources.”2015. https://www.naccho.org/blog/articles/hurricane-and-flooding-preparedness-resources.
130 National Association of County and City Health Officials. “2022 Preparedness Profile Study.” 2023. https://www.naccho.org/uploads/downloadable-resources/2022PrepProfile-PREVIEWREPORT.pdf.
131 National Health Security Preparedness Index. “Measures List: National Health Security Preparedness Index, 2021 Release.” 2021. https://nhspi.org/wp-content/uploads/2021/06/2021-NHSPI-Measure-List.pdf.
132 Qari, S.H., H.R. Yusuf, S.L. Groseclose, M.R. Leinhos, and E.G. Carbone. “Public Health Emergency Preparedness System Evaluation Criteria and Performance Metrics: A Review of Contributions of the CDC-Funded Preparedness and Emergency Response Research Centers.” Disaster Medicine and Public Health Preparedness, vol. 13, no. 3, 2019, pp. 626–638. 10.1017/dmp.2018.110.30419972
133 Government Accountability Office. “COVID-19: Pandemic Lessons Highlight the Need for Public health Situational Network.” 2022. https://www.gao.gov/products/gao-22-104600.
134 Ibid.
135 Lorenzoni, Nina, Stephanie Kainrath, Maria Unterholzner, and Harold Stummer. "Instruments for Disaster Preparedness Evaluation: A Scoping Review." Australian Journal of Emergency Management, vol. 37, no. 3, 2022, pp. 56.
136 Ibid.
137 Qari, S.H., H.R. Yusuf, S.L. Groseclose, M.R. Leinhos, and E.G. Carbone. “Public Health Emergency Preparedness System Evaluation Criteria and Performance Metrics: A Review of Contributions of the CDC-Funded Preparedness and Emergency Response Research Centers.” Disaster Medicine and Public Health Preparedness, vol. 13, no. 3, 2019, pp. 626–638. 10.1017/dmp.2018.110.30419972
138 Institute of Medicine Committee on Post-Disaster Recovery of a Community's Public Health, Medical, and Social Services. “Healthy, resilient, and sustainable communities after disasters: strategies, opportunities, and planning for recovery.” Washington (DC): National Academies Press (US); 2015 Sep 10. Available from: https://www.ncbi.nlm.nih.gov/books/NBK316532/ doi: 10.17226/18996.
139 Stribling, J., A. Clifton, G. McGill, and K. de Vries. “Examining the UK Covid-19 Mortality Paradox: Pandemic Preparedness, Healthcare Expenditure, and the Nursing Workforce.” Journal of Advanced Nursing, vol. 76, no. 12, 2020, pp. 3218–3227. 10.1111/jan.14562.32914471
140 Kaiser, M.A., T.Y. Chen, and P. Gluckman. “Should Policy Makers Trust Composite Indices? A Commentary on the Pitfalls of Inappropriate Indices for Policy Formation.” Health Research Policy and Systems, vol. 19, no.1, March 2021. 10.1186/s12961-021-00702-4.
141 Keim, M.E., and A.P. Lovallo. “Validity of the National Health Security Preparedness Index as a Predictor of Excess COVID-19 Mortality.” Prehospital and Disaster Medicine, vol. 36, no. 2, 2021, pp. 141–144. 10.1017/S1049023X20001521.33397547
142 Choo, E.K. “COVID-19 Fault Lines.” Lancet, vol. 395, no. 10233, 2020, pp. 1333. 10.1016/S0140-6736(20)30812-6.32334693
143 Liao, T.F., and F. De Maio. “Association of Social and Economic Inequality with Coronavirus Disease 2019 Incidence and Mortality Across US Counties.” JAMA Network Open, vol. 4, no. 1, 2021, article e2034578. 10.1001/jamanetworkopen.2020.34578.33471120
144 Mays, G., and M. Childress. “2021 Release of National Health Security Preparedness Index.” University of Colorado, Colorado School of Public Health, June 2021.
145 Centers for Disease Control and Prevention. “Public Health Response Readiness Framework: 2024-–2028 Program Priorities – Defines Excellence in Response Operations.” 2024. https://www.cdc.gov/orr/readiness/phep/00_docs/CDC-PHEP-Response-Readiness-Framework_January-2024_508c.pdf.
146 American Medical Association, Planned Parenthood Federation of America, American Association of Public Health Physicians, National Birth Equity Collaborative, American College of Preventive Medicine, American Public Health Association, For the Culture Consulting, LLC, and New York City Pandemic Response Institute. “Embedding Equity in Crisis Preparedness and Response.” 2023. https://www.ama-assn.org/about/ama-center-health-equity/embedding-equity-crisis-preparedness-and-response-health-systems. Accessed May 10, 2024.
147 Congressional Research Service. “Tracking COVID-19: U.S. Public Health Surveillance and Data.” 2020. https://crsreports.congress.gov/product/pdf/R/R46588.
148 Centers for Disease Control and Prevention. “Data Modernization Initiative website.” n.d. https://www.cdc.gov/surveillance/data-modernization/index.html. Accessed May 2, 2024.
149 National Academies of Sciences, Engineering, and Medicine. “Evidence Based Practice for Public Health Emergency Preparedness and Response.” 2020.
150 Samet, J. and R.C. Brownson. “Reimagining Public Health: Mapping a Path Forward”. Health Affairs, vol. 43, no. 6, 2024, pp. 750 – 758. 10.1377/hlthaff.2024.00007.38830167
151 Lichiello, P., and B. Turnock. Guidebook to Performance Management. 1999. https://www.phf.org/resourcestools/documents/pmcguidebook.pdf.
152 Ibid.
153 Roper, W., and B. Mays. “Performance Measurement in Public Health: Conceptual and Methodological Issues in Building the Science Base.” Journal of Public Health, September 2000.
154 McDavid, J. C., and L.R.L. Hawthorn, L. R. L. Program Evaluation and Performance Measurement: An Introduction to Practice. Sage Publications, Inc, 2006.
155 Roper, W., and B. Mays. “Performance Measurement in Public Health: Conceptual and Methodological Issues in Building the Science Base.” Journal of Public Health, September 2000.
156 Ibid.
157 Cox, R., and M. Hamlen. “Community Disaster Resilience and the Rural Resilience Index.” American Behavioral Scientist, vol. 59, no. 2, February 2015.
158 Lorenzoni, Nina, Stephanie Kainrath, Maria Unterholzner, and Harold Stummer. "Instruments for Disaster Preparedness Evaluation: A Scoping Review." Australian Journal of Emergency Management, vol. 37, no. 3, 2022, pp. 56.
159 Glik, D.C., D.P. Eisenman, I. Donatello, A. Afifi, M. Stajura, M.L. Prelip, J. Sammartinova, “Reliability and Validity of the Assessment for Disaster Engagement with Partners Tool (ADEPT) for Local Health Departments.” Public Health Reports, vol. 129, no. 6, suppl. 4, 2014, pp. 77–86. 10.1177/00333549141296S411.25355978
160 Acosta, J.D., L. Burgette, A. Chandra, D.P. Eisenman, I. Gonzalez, D. Varda, and L. Xenakis. “How Community and Public Health Partnerships Contribute to Disaster Recovery and Resilience.” Disaster Medicine and Public Health Preparedness, vol. 12, no. 5, 2018, pp. 635–643. 10.1017/dmp.2017.130.29388518
161 Dorn, B.C., E. Savoia, M.A. Testa, M.A. Stoto, and L.J. Marcus. “Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance.” Public Health Reports, vol. 122, no. 3, 2007, pp. 329–38. doi: 10.1177/003335490712200306. PMID: 17518304; PMCID: PMC1847495. Development of a Survey Instrument to Measure Connectivity to Evaluate National Public Health Preparedness and Response Performance - PMC (nih.gov).17518304
162 Ibid.
163 Technical Resources, Assistance Center, and Information Exchange. "ASPR TRACIE Emergency Preparedness Information Modules for Nurses in Acute Care Settings," February 2022. https://files.asprtracie.hhs.gov/documents/aspr-tracie-emergency-preparedness-information-modules-for-nurses-and-economic-framework.pdf. Accessed May 10, 2024.
164 Society for Healthcare Epidemiology of America. "Outbreak Response Training Program." https://learningce.shea-online.org/content/sheacdc-outbreak-response-training-program-ortp#group-tabs-node-course-default1 (https://learningce.shea/-online.org/content/sheacdc-outbreak-response-training-program-ortp#group-tabs-node-course-default1). Accessed May 10, 2024.
165 Haan, Katherine. "Best Learning Management Systems (LMS) of 2024." Forbes Advisor, April 8, 2024. https://www.forbes.com/advisor/business/best-learning-management-systems/#:~:text=Learning%20management%20systems%2C%20or%20LMS%2C%20are%20software%20platforms,as%20to%20provide%20compliance%20training%20or%20customer%20education. Accessed May 10, 2024.
166 National Association of County and City Health Officials. “2022 Preparedness Profile Study.” 2023. https://www.naccho.org/uploads/downloadable-resources/2022PrepProfile-PREVIEWREPORT.pdf.
167 Choo, E.K. “COVID-19 Fault Lines.” Lancet, vol. 395, no. 10233, 2020, pp. 1333. 10.1016/S0140-6736(20)30812-6;32334693
Liao, T.F., and F. De Maio. “Association of Social and Economic Inequality with Coronavirus Disease 2019 Incidence and Mortality Across US Counties.” JAMA Network Open, vol. 4, no. 1, 2021, article e2034578. 10.1001/jamanetworkopen.2020.34578.33471120
168 Krieger, Nancy, Christian Testa, Jarvis T. Chen, William P. Hanage, and McGregor Alecia J. . “Relationship of Political Ideology of U.S. Federal and State Elected Officials and Key COVID Pandemic Outcomes Following Vaccine Rollout to Adults: April 2021–March 2022.” The Lancet Regional Health - Americas, vol. 16, 2022, article 100384. 10.1016/j.lana.2022.100384; Technical Expert Panel.36338898
169 Stoto, M., and C. Nelson. “Measuring and Assessing Public Health Emergency Preparedness: A Methodological Primer.” SSRN, August 2023. 10.2139/ssrn.4538548; Technical Expert Panel.
170 Brown, Lisa M., Kathryn Hyer, and Polivka-West LuMarie , "A comparative study of laws, rules, codes and other influences on nursing homes' disaster preparedness in the Gulf Coast states." Behavioral Sciences & the Law, vol. 25, no. 5, September 2007, pp. 655–675. 10.1002/bsl.785.17899530
171 Botoseneanu, A., H. Wu, J. Wasserman, P.D. Jacobson, "Achieving public health legal preparedness: how dissonant views on public health law threaten emergency preparedness and response." Journal of Public Health, vol. 33, no. 3, September 2011, pp. 361–368. 10.1093/pubmed/fdq092.21059686
172 Chowdhury, P., S. Kumar Paul, S. Kaisar, and Moktadir Md. A. . "COVID-19 Pandemic Related Supply Chain Studies: A Systematic Review. Trnsp Res E Logist Transp Rev. April 2021, 148: 102271. doi: 10.1016/j.tre.2021.102271.
173 DeSalvo, K., B. Hughes, M. Bassett, G. Benjamin, M. Fraser, S. Galea, N. Garcia, and J. Howard. 2021. “Public Health COVID-19 Impact Assessment: Lessons Learned and Compelling Needs.” NAM Perspectives. Discussion Paper, National Academy of Medicine, Washington, DC. 10.31478/202104c.
174 Burke, Marshall, Anne Driscoli, Sam Huft-Neal, Jiani Xue, Jennifer Burney, and Michael Wara, "The changing risk and burden of wildfire in the United States." PNAS vol. 118, no. 2, 2021. 10.1073/pnas.2011048118.
175 Mannucci, Simona, Federica Rosso, Alessandro D'Amico, Gabriele Bernardini, and Michele Morganti, "Flood resilience and adaptation in the built environment: how far along are we?" Sustainability, vol. 14 no. 7, March 2022, 4096; 10.3390/su14074096.
176 Brown, Lisa M., Kathryn Hyer, and LuMarie Polivka-West, "A comparative study of laws, rules, codes and other influences on nursing homes' disaster preparedness in the Gulf Coast states." Behavioral Sciences & the Law, vol. 25, no. 5, September 2007, pp. 655–675. 10.1002/bsl.785.17899530
177 Choo, E.K. “COVID-19 Fault Lines.” Lancet, vol. 395, no. 10233, 2020, pp. 1333. 10.1016/S0140-6736(20)30812-6;32334693
Liao, T.F., and F. De Maio. “Association of Social and Economic Inequality with Coronavirus Disease 2019 Incidence and Mortality Across US Counties.” JAMA Network Open, vol. 4, no. 1, 2021, article e2034578. 10.1001/jamanetworkopen.2020.34578.33471120
178 Centers for Disease Control and Prevention. “Public Health Response Readiness Framework: 2024–2028 Program Priorities – Defines Excellence in Response Operations.” CDC. https://www.cdc.gov/orr/readiness/phep/00_docs/CDC-PHEP-Response-Readiness-Framework_January-2024_508c.pdf.
179 Mays, G., and M. Childress. “2021 Release of National Health Security Preparedness Index.” University of Colorado, Colorado School of Public Health, June 2021.
180 Federal Emergency Management Agency. “After-Action Review User Guide.” November 2023. https://preptoolkit.fema.gov/documents/d/cip-citap/after_action_review_user_guide_november_2023_f?download=true.
181 Federal Emergency Management Agency. “National Preparedness Goal.” March 2023. https://www.fema.gov/emergency-managers/national-preparedness/goal. Accessed May 6, 2024
182 National Academies of Sciences, Engineering, and Medicine. “Evidence Based Practice for Public Health Emergency Preparedness and Response.” 2020.
183 Knox, C. C. “Systematic Analysis of After-Action Reports: A Plan Evaluation Methodological Approach.” Nat. Hazards Rev., vol. 22, no. 4, 2021. https://ascelibrary.org/doi/10.1061/%28ASCE%29NH.1527-6996.0000519.
184 FEMA. “Homeland Security Exercise Evaluation Program.” Undated. https://preptoolkit.fema.gov/web/hseepresources.
185 TRACIE. “COVID After-Action Report Resources and Examples.” January 19, 2023. https://files.asprtracie.hhs.gov/documents/aspr-tracie-covid-19-after-action-reports---7-21-2021-508.pdf.
186 Naik, R., N. Maxwell, T. Jones, and S. A. Dopson. "Public Health Emergency Preparedness: Qualitative Analysis of After-Action Reports. Disaster Medicine and Public Health Preparedness, vol. 17, 2023, e523. doi: 10.1017/dmp.2023.201.37941114
187 Piltch-Loeb, R.N., C. Nelson, J. Kraemer, E. Savoia, and M. Stoto. “s.” Public Health Reports, vol. 129, no. 6, November 2014, pp. 28–34. 10.1177/00333549141296S405.25355972
188 Administration for Strategic Preparedness and Response. “2019–2023 Hospital Preparedness Program: Performance Measures Implementation Guidance.” 2022. https://aspr.hhs.gov/HealthCareReadiness/guidance/Documents/2019-2023-HPP-Performance-Measures-Implementation-Guidance-8Nov22.pdf.