# Acknowledgments

The authors wish to thank the Technical Expert Panel members (Appendix D) for their valuable contributions to this work, as well as Chris Palo, Effie Metropoulos, Jill Miller, Dorothy Bellow, and Sheryl Friedlander at Mathematica. We would also like to acknowledge the following individuals:

- Kevin Yeskey, MD, MDB Inc.
  Nicholas Cagliuso, PhD, MPH, MDB Inc.
  Allison Kolbe, PhD, ASPE
  Deborah Porterfield, MD, MPH, ASPE
  Contract Officer’s Representative, Marsha Clarke, PhD, ASPE
  Kim Nguyen, DVM, MPH, ASPE
  Kathleen Miller PhD, MS, ASPE
  Laurin Grabowsky, MSc, ASPE
  Jessica White, MPP, ASPE