# Executive Summary

## A Background

A wide range of recent domestic disasters—from wildfires to the COVID-19 pandemic—have highlighted the challenge of preparing for large-scale public health emergencies. Inadequate preparation for these disasters has resulted in preventable loss of life, diminished public trust in federal, state, tribal, local, and territorial (STLT) governments, and ongoing confusion about actions needed to improve preparedness.

To help the federal government and STLT jurisdictions better prepare for emergencies, there is a need to understand how prepared different jurisdictions are for various emergencies. Understanding a jurisdiction’s level of preparedness can inform resource allocation and identify actions that the federal government and STLT jurisdictions can take to bolster preparedness, such as developing formal response plans, training public health and health staff, or forming contractual agreements with partner organizations. However, assessing whether a jurisdiction is prepared for different emergencies is inherently complex and there is a lack of consensus among practitioners and scholars on how to approach preparedness measurement. Measurement tools introduced in recent decades have numerous limitations, such as inconsistently defining preparedness and its goals, relying on subjective agency assessments of the standards and capabilities that contribute to preparedness, and failing to provide an evidence base for measures. The cross-sectoral, cross-jurisdictional nature of public health systems adds to the complexity of preparedness measurement: because of the many agencies and organizations involved in emergency response efforts, it is challenging to understand how performance should be measured and accountability distributed across these partners. Further, the singularity of public health emergencies makes it difficult to assess whether key takeaways from one disaster will apply to the next.

In response to these challenges, the U.S. Department of Health and Human Services Office of the Assistant Secretary for Planning and Evaluation (ASPE) funded a study to address 1) the current state of metrics for public health and health care preparedness in the United States, including gaps in existing metrics and limitations of existing metrics identified during the COVID-19 pandemic and 2) strategies to potentially improve measurement of public health and health care preparedness and address the gaps and limitations in current metrics. The methods for this study include a synthesis of key findings from a targeted environmental scan of domestic preparedness metrics and a technical expert panel (TEP) made up of representatives from federal agencies, public health and healthcare organizations, and academic institutions, with diverse experience in preparedness measurement and emergency response.

## B The current state of public health and health care preparedness metrics in the United States

We conducted an environmental scan to understand tools currently available to assess STLT preparedness, including indices, measure sets, and other instruments such as self-administered preparedness surveys.^I^ We identified nine tools to measure STLT emergency preparedness, including three that have also been used to assess national preparedness in the United States (Exhibit ES.1).

Exhibit ES.1 List and description of tools to assess STLT public health and healthcare preparedness

Tool | Description
Tools for internal and external stakeholders
Community Outbreak Preparedness Index (COPI) | Assesses county-level preparedness for infectious disease outbreaks using publicly available data
Hospital Medical Surge Preparedness Index (HMSPI) | Evaluates the capacity of hospitals to handle patient surges during mass casualty events, using over 120 measures from publicly available data sources
Hospital Preparedness Program (HPP) performance measure set | Assesses preparedness of HPP funding recipients based on 22 performance measures reported by recipients and disseminated broadly
National Health Security Preparedness Index (NHSPI) | Generates a composite preparedness score for states, territories, and the nation overall based on 130 measures derived from publicly available data sources
Trust for America’s Health (TFAH) Ready or Not tool | Evaluates states’ preparedness for public health emergencies using a targeted set of 10 measures largely derived from the NHSPI
Self-administered tools for internal use by STLT jurisdictions
Assessment for Disaster Engagement with Partners Tool (ADEPT) | Summarizes the frequency and nature of activities related to disaster preparedness, response, and recovery that local health departments engage in with community-based organizations, using a 15-item index for use by local health departments
Connectivity Measurement Tool | Quantifies the level of connectivity of different organizations and systems involved in public health preparedness across 28 items
Preparedness Capacity Assessment Survey (PCAS) | Creates an aggregate score summarizing preparedness of local health departments
Rapid Urban Health Security Assessment (RUHSA) | Evaluates local-level health security capacities across 46 measures

We present a summary of key characteristics of these tools, as well as gaps and limitations as identified by the literature and the TEP, in Exhibit ES.2.

Exhibit ES.2 Summary of key characteristics of existing public health and health care preparedness metrics and their gaps and limitations

Characteristic | Summary of existing metrics and their gaps/ limitations
Purpose and users | Tools vary in their target audience:; - Five tools are intended for internal and external stakeholders. Results from these tools are publicly disseminated for use by a broad audience of federal and STLT policy makers, public health and health care organizations, and the general public.; - Four tools require self-administration and are intended for internal users, such as local health department staff and their partners.; Gaps and limitations: Tools intended for broad internal and external audiences may not feel actionable for STLT users that face challenges interpreting and adapting scores to their local contexts.
Jurisdiction levels | Of the nine STLT tools:; - Two tools (the NHSPI and the TFAH tool) assess preparedness at the state and territorial level; in addition, the HPP measure set can be aggregated at the state level.; - Seven tools assess preparedness within states and territories at the local level (e.g., county, local health department, or hospital level).; - Results from two tools—the NHSPI and HPP measure set—are routinely aggregated at the national level to present a snapshot of national preparedness. In addition, the TFAH tool groups states into tiers based on scores for each measure, which can be used to assess national preparedness (for example, by assessing the number or percentage of states in the highest or lowest performing tier for each measure to assess relative strengths and weaknesses across the United States).; - None of the tools were adapted for tribal communities.; Gaps and limitations: There is no comprehensive all-hazards index to measure and guide local jurisdictions’ emergency preparedness efforts. In addition, there were no preparedness tools tailored to tribal communities.
Factors measured | Tools vary in the breadth of factors that they measure. For example:; - The NHSPI and COPI take a comprehensive approach to measuring preparedness across the emergency management cycle (i.e., prevention, protection, mitigation, response, and recovery) and include “proactive” measures of preparedness that assess social vulnerability and resilience.; - Other tools are more focused on specific aspects of preparedness (for example, the HMSPI focuses on surge capacity and the Connectivity Measurement Tool focuses on perceptions of partnerships).; Gaps and limitations: Existing tools inadequately capture several important factors that affect preparedness, including strength of cross-sector collaboration, individual readiness and training of the workforce, administrative capacity, political factors, social vulnerability, and public trust.
Types of disasters addressed | Eight out of nine preparedness tools take an all-hazards approach to measurement, assessing measures of preparedness applicable to a wide range of disasters.; Gaps and limitations: There is a lack of disaster-specific tools; all-hazards tools may not reliably predict outcomes for all types of emergencies and may be challenging for STLT users to interpret.
Data sources and availability | Four tools leverage data from nearly 100 different public sources, including national surveys, government agencies, and associations; the other five tools are designed for self-reporting/self-administration.; Gaps and limitations: There is a lack of publicly available data at the local level. In addition, there are limitations in the availability of timely data, with some sources being updated infrequently.

In addition to the gaps noted above, the COVID-19 pandemic exposed other weaknesses that need to be addressed to improve emergency preparedness and preparedness measurement. For example:

/ Many preparedness tools—including the NHSPI, TFAH, and other prominent global tools—were not valid predictors of COVID-19 outcomes, such as excess mortality rates. This underscores the need to explore ways to improve measurement within existing tools and consider whether all-hazards tools like the NHSPI are the best way to assess preparedness for the wide range of unique emergencies that the country is likely to face.
/ A variety of critical factors that affect outcomes are not accounted for in current preparedness measures, such as partnerships, political will, and public trust, among others. Moving forward, it will be important to consider ways to measure these factors and incorporate them in preparedness metrics.
/ The disparate impacts of the COVID-19 pandemic on socially vulnerable communities, who suffered higher incidence of COVID-19 infections and deaths, highlight the need to embed equity in how jurisdictions prepare for emergencies and thus, in how we measure communities’ preparedness and assess their vulnerabilities.
/ Finally, the COVID-19 pandemic exposed significant weaknesses in the public health data and surveillance infrastructure, as evidenced by challenges with reporting and tracking lab test results, lack of interoperability across health and public health reporting systems, and gaps in the types of data that are collected and tracked. Investments in data infrastructure could help improve preparedness metrics, especially at the local level where measurement is limited by the availability of standardized, timely data.

## C Strategies to improve measurement of public health and health care preparedness

Given the gaps and limitations in existing tools and inherent challenges in measuring preparedness, there is an opportunity to apply lessons learned from the COVID-19 pandemic to pursue development of improved metrics. These efforts must be rooted in an understanding of the ideal attributes of public health preparedness measures, so that there are set criteria against which future metrics could be evaluated. We present ten attributes in this report, informed by current public health performance measurement literature. Then, considering these key attributes and feedback from the TEP, we outline four strategies and examples of associated follow-up efforts that could potentially advance preparedness measurement, summarized in Exhibit ES.3.

Exhibit ES.3 Four strategies that could potentially advance preparedness measurement, and potential follow-up efforts for consideration

Strategies | Potential follow-up efforts
1. Address gaps in existing metrics by developing or refining important measures of preparedness and supplementing preparedness metrics with contextual data. | Low-intensity efforts could include:; - Advancing individual training and measurement of training by working with professional associations.; - Evaluating existing online preparedness curricula to set a foundation for measurement of individual preparedness.; - Exploring degree program accreditation as a tool to improve readiness of future public health professionals and set a foundation for a national measure of individual preparedness.; Medium-intensity efforts could include:; - Developing new trainings to fill gaps, supporting improvement on future measurement of individual preparedness.; - Advancing measurement on the strength of essential partnerships; - Investigating contextual factors critical to response and outcomes.; High-intensity efforts could include:; - Improving measurement of administrative response capabilities and providing support to help STLT jurisdictions overcome barriers.; - Developing a national-level measure or measures corresponding to administrative response capability.
2. Improve how health equity is addressed in preparedness metrics by engaging underserved communities in continuous efforts to advance measurement and considering social vulnerability data together with preparedness measures. | A low-intensity effort could include:; - Developing recommendations for an effective approach to present social and health vulnerability indicators with or within preparedness indices.; A medium- to high-intensity effort (depending on the number of communities included) could include:; - Identifying locally appropriate metrics focused on health equity to advance equity-focused preparedness measurement in communities, such as metrics summarizing the preparedness level of neighborhoods disproportionately impacted by COVID-19 and at elevated risk for specific types of emergencies (for example, flooding in a low-lying area or floodplain).
3. Improve source data and use additional analyses to enhance the availability, responsiveness, and salience of preparedness metrics. | Low-intensity efforts could include:; - Exploring the feasibility of using artificial intelligence with After Action Reports (AARs), to facilitate scaled up qualitative analysis to identify themes.; - Exploring stakeholder receptiveness to implementing a metadata template for AARs, to facilitate synthesizing patterns across AARs.; - Exploring the feasibility and benefits of using non-public data sources, such as data from the Real-World Incident Reporting and Evaluation tool or others, to advance the evidence base for preparedness metrics.; Medium-intensity efforts could include:; - Analyzing AARs on a large scale to identify key themes.; - Facilitating improvement of AARs’ quality and availability, through an organized peer review process and support to ensure AARs are created and shared following all disasters.; - Undertaking research using non-public data sources to advance the evidence base for preparedness metrics.; A high-intensity effort could include:; - Identifying and developing automated data solutions that would reduce reporting burden.
4. Enhance actionability and understandability of metrics by developing and disseminating information on exemplars. | A low-intensity effort could include:; - Conducting a needs assessment to identify jurisdiction types, organizations, and disaster types most in need of exemplar models, and a landscape assessment to identify existing strong examples and find important gaps.; A medium-intensity effort could include:; - Developing case studies to fill identified needs for exemplar models and disseminate them to relevant audiences.

Notes: Low-intensity=likely to require one to three staff working for less than a year; high-intensity=those that involve large-scale data collections or system changes; medium-intensity=efforts likely to fall between the low- and high-intensity ranges. Low-intensity and italicized efforts could begin when resources are available. Italicized medium and high-intensity efforts indicate those not dependent on low-intensity efforts. Medium- and high-intensity efforts not italicized would best be structured using results from the low-intensity efforts listed.

Implementing these strategies would require collaboration across a range of stakeholders, including federal agencies, STLT jurisdictions, public health and health care organizations and their partners, and researchers. In addition, these strategies would require investments that need to be considered against the many competing priorities that public health systems face. The low-intensity efforts listed above often set up and help structure suggested medium- and high-intensity efforts and would be good places to start. However, several of the suggestions for medium- or high-intensity efforts could begin without additional preliminary work as soon as resources permit; those are italicized in Exhibit ES.3. The specific selection of where to begin depends, as a practical matter, on how managers within the relevant agencies find the efforts well-matched with existing work, resources, and program opportunities; but even implementing a few of the efforts listed in Exhibit ES.3 could help agencies make incremental progress. Ultimately, the availability of better tools to measure and understand gaps in preparedness against specific threats could inform federal and state resource allocation and help set priorities to improve preparedness of public health and healthcare system for the next public health threat. In the hands of strong leadership, better measurement can also catalyze and enable improvement, resulting in a better-prepared nation.

I We define indices as tools that assess preparedness across a range of measures and create a composite score summarizing a jurisdiction’s preparedness. Measure sets similarly assess preparedness across a variety of measures but do not produce a summary statistic.