# III Strategies to Improve Measurement of Public Health and Health Care Preparedness

Gaps and challenges in current preparedness metrics can inform refinement of domestic preparedness metrics going forward. Considering takeaways from Chapter II, this chapter focuses on ways to improve preparedness measurement by addressing the following two research questions:

1. What key attributes should public health and health care preparedness measures and indices have, and what gaps from Chapter II do these attributes address?
2. What strategies should potentially be explored to improve measurement of public health and health care preparedness?

## A What key attributes should new public health and health care preparedness measures have, and what gaps would they address?

To identify strategies for improving preparedness measurement, researchers and policymakers should begin by (1) examining the ideal attributes of measures and indices, and (2) considering how they could fill the gaps revealed here. Defining key attributes or necessary characteristics of metrics provides a set of criteria to assess measures and indices against. Exhibit III.1 lists 10 key attributes to consider for preparedness metrics, along with the gaps they address. This list is based on the attributes put forth by Lichiello and Turnock in their Guidebook for Performance Measurement.^151^ The research team then drew on existing literature on public health measurement to consider modifications to the attributes. These 10 attributes were ultimately organized into three categories:

/ Research-dependent attributes—including importance, validity, and reliability—require quantitative analysis to understand whether the measure or index is relevant, accurate, and repeatable.
/ Data-source dependent attributes—including availability, responsiveness, and completeness—concern access to timely data sources that underlie measures and indices.
/ Ready for real-world use attributes—including understandability, actionability, credibility, and flexibility/adaptability—support a measure or index’s ability to be used in practice.

Eight of the attributes highlighted in Exhibit III.1 apply to both the measures themselves and to indices; two of the attributes—completeness and flexibility and adaptability—apply solely to indices. Lichiello and Turnock noted that there is a risk to complete and accurate reporting if there will be negative consequences for staff or organizations that report low scores. Lichiello and Turnock described this as a need for “abuse-proof” measurement,^152^ while the TEP noted a need to avoid political leaders fearing retribution over low scores.

Exhibit III.1 Key attributes of preparedness measures and the gaps they address^a^

No. | Attribute | Description and risk if not met | Current gaps or weaknesses addressed
Research-dependent
1 | Importance | Reflects a structure, process, or outcome with a large impact on health; demonstrates substantial variation reflecting meaningful underlying differences;^153^ is directly related to objectives.; Risk if not met: The measure or index may not focus on activities that preserve life or improve health or other key outcomes following an emergency. | Metrics reflect a wide range of competing capabilities and frameworks set forth by federal agencies and researchers, with little evidence base for selection of their components.
2 | Validity | Captures the essence of what it purports to measure, instead of correlated characteristics.; Risk if not met: The measure or index may inaccurately indicate a jurisdiction is prepared, when in reality it is not. | High performance on preparedness metrics did not predict COVID-19 outcomes for many indices; there is a lack of evidence supporting the validity of measures in practice.
3 | Reliability | Has a high likelihood of yielding the same results in repeated trials, so there are low levels of random error in measurement.; Risk if not met: The measure or index may accurately predict preparedness in one scenario, but not others. | There is a lack of evidence supporting the reliability of measures and indices in practice.
Data source-dependent
4 | Availability | Readily available with means on hand; accessible, ongoing sources of data.^154^; Risk if not met: The measure or index will require time-intensive data collection and reporting, displacing focus that could be spent on preparedness activities. | Data limitations have hindered development of comprehensive local indices. Lack of data makes it difficult to measure some aspects of preparedness, such as the strength of partnerships. Challenges with interoperability impede timely data sharing, a critical component of preparedness.
5 | Responsiveness | Able to detect change; properly calibrated and sensitive enough to pick up important changes.^155^; Risk if not met: The measure or index is not up to date when an incident occurs; that is, a capacity that appeared adequate from older data is not there. | Gaps in timely data sources and lack of dynamic measures of preparedness limit existing indices’ ability to register critical changes in preparedness.
6 | Completeness^b^ | An emergency preparedness index should ideally cover all important aspects of emergency preparedness that affect outcomes.; Risk if not met: The index will fail to predict the quality of response and outcomes in an emergency. For example, if the index captures a wide range of factors that affect preparedness but does not include measures of surge capacity, a jurisdiction may be ill-equipped to meet demand for health services, leading to increased preventable mortality following a disaster. | Existing metrics fail to consider the wide range of factors that affect preparedness, such as the strength of partnerships, individual training, and administrative capabilities.; There is a lack of equity-focused preparedness metrics to identify potential inequities in crisis preparedness and response.
Ready for real-world use
7 | Understandability | Easily understood by all, with minimal explanation.; Risk if not met: The measure or index is unlikely to be used in practice or could be used incorrectly. | All-hazards indices and tools that compound preparedness scores across a range of measures may be difficult to interpret, especially at the local level, and there are few hazard-specific preparedness tools available at the STLT level.
8 | Actionability | Process or condition within the organization’s control.^156^; Risk if not met: The measure or index is unlikely to improve readiness or be used in practice. | Many indices lack benchmarks to help jurisdictions set goals, track progress, and take action to improve preparedness.; The lack of regularly updated data sources makes it challenging to measure factors that change quickly, limiting the actionability of preparedness measures that rely on outdated data.
9 | Credibility | Supported by stakeholders.; Risk if not met: The measure or index is unlikely to be used in practice. | STLT jurisdictions have described challenges using existing tools, which may be related to lack of engagement of STLT jurisdictions in the development and refinement of metrics.
10 | Flexibility and adaptability^b^ | An index should be adaptable across jurisdiction types. For example, an index may need to have required and optional components that could be tailored to a jurisdiction and its specific hazards.^157,158^; Risk if not met: The index will not accurately capture preparedness across communities with different risks and/or may not be feasibly used across communities with different public health structures. | There is a lack of metrics that can be adapted to the unique needs and risks of STLT jurisdictions in a way that informs their efforts to improve preparedness.

a Attributes 1–5, 7, and 9 are adapted from Lichiello and Turnock’s Guidebook for Performance Measurement;^146^ additional references are as noted.

b Attributes 6 and 10 apply to indices only.

The COVID-19 experience suggests that federal, state, local, and nongovernmental organizations could establish priorities for preparedness measurement—including assessing tradeoffs between measure attributes and the feasibility of various measurement strategies—to make incremental progress as resources become available. One of the TEP members lamented the lack of progress in the past decade on improving availability of preparedness measurement metrics. A variety of factors have limited progress, including constrained resources and the challenge of prioritizing how to invest them. More recently, fading memories of just how ill-prepared the U.S. was during the COVID-19 public health emergency could also be a factor. To help ASPE and others capitalize on ASPE’s investment in this project, in the next section we outline a series of strategies, along with their likely resource intensity, for consideration to help build forward momentum on preparedness measurement activities.

## B What strategies could potentially be explored to improve measurement of public health and health care preparedness?

Given the challenges discussed, there is an opportunity to pursue development of improved measures and indices that have the attributes described above in Exhibit III.1 and that address the gaps in metrics described in Chapter II. This section describes four strategies to advance preparedness measurement (Exhibit III.2).

For each of the four proposed strategies, we present tables that outline potential action steps that could support achievement of these strategies (Exhibits III.5, III.6, III.9, and III.10). For each action step, we also estimate its resource intensity—low, medium, or high—to shed light on strategy feasibility. Low-intensity strategies are those likely to require one to three staff working for less than a year; high-intensity strategies are those that involve large-scale data collections or system changes; and medium-intensity strategies capture efforts likely to fall between the low- and high-intensity ranges. Some of the medium- and high-intensity strategies would benefit from building on the results of listed low-intensity strategies, while others—those we have italicized—could begin as soon as resources are available.

Exhibit III.2 Four strategies that could potentially advance preparedness measurement

1. Address gaps in existing metrics by developing or refining important measures of preparedness and supplementing preparedness metrics with contextual data.
2. Improve how health equity is addressed in preparedness metrics by engaging underserved communities in continuous efforts to advance measurement and considering social vulnerability data together with preparedness measures.
3. Improve source data and use additional analysis to enhance the availability, responsiveness, and salience of preparedness metrics.
4. Enhance actionability and understandability of metrics by developing and disseminating information on exemplars.

### Strategy #1: Address gaps in existing metrics by developing or refining important measures of preparedness and supplementing preparedness metrics with contextual data.

Developing new measures for critical aspects of preparedness would help fill identified gaps in current measures and improve current measurement tools. As shown in Exhibit III.1, a key attribute of a desirable measure is a proven link between the activity and outcomes. Further, indices should incorporate all important aspects of emergency preparedness to achieve completeness. As discussed during the TEP, several factors that contribute to preparedness are missing from current measures and indices. Important preparedness factors that could be considered in future measure development work include individual preparedness, cross-sector partnerships, and administrative response capabilities, each discussed further below, with examples for potential follow up actions listed in Exhibit III.5. We also discuss the importance of pairing supplemental data on social, political, economic, and environmental factors with preparedness metrics, acknowledging that data sources to measure these factors are not currently available on an ongoing basis, meaning the cost of collecting these data would need to be weighed against the importance of these measures.

/ Individual readiness of the public health and health care workforce. As highlighted in Chapter II, TEP members noted the importance of measuring individual readiness—that is, whether public health and health care workers have the right training to respond to public health emergencies—in addition to organizational preparedness. In practice, this may be easier said than done. For example, during the COVID-19 public health emergency, guidance for managing the response was sometimes emerging locally and disparately, due to the novel situation, and there were limited and sometimes lagged or incomplete data to inform that guidance. While neither individual nor organizational preparedness training plans can account for all possible emergency scenarios with challenging conditions like the COVID-19 pandemic, a better-trained workforce might mitigate some future challenges. To the extent that policymakers need to issue local guidance as with COVID-19, they should also consider what supplemental training or mentorship may be needed for health care workers to effectively implement their guidance.
  Beyond individual training, some degree of cross-training might also improve preparedness, since during the COVID-19 public health emergency, many public health and health care professionals had to assume roles for which they were not trained.^162^ Although there are many options for training public health and health care workers and leaders on emergency readiness,^163,164^ the literature did not describe any metrics that report the percentage of the public health or health care workforce that have recently completed relevant, evidence-based training. Learning management systems, which are widely available online, can easily collect and report the kinds of data that could be useful, such as the specific roles of those trained (leader, health care worker, and so on), when they had their last training, percentage of employees trained, and so on.^165^ In conjunction with measuring individual readiness, there may be an opportunity to improve or expand existing preparedness programs and clarify a minimum training expectation to ensure that all the types of professionals necessary for an effective response are trained.
/ Cross-sector partnerships. As noted in Chapter II, partnerships between public health, health care, and other sectors such as community-based organizations are critical to emergency response. To better understand the strength of a jurisdiction’s partnerships, a standardized survey approach that preserves anonymity of respondents could objectively capture this information. Some survey tools exist to measure partnerships (Exhibit III.3). Going forward, work could focus on reviewing existing tools and considering whether they could be adapted for widespread use, and on exploring the feasibility of incorporating a survey-based measure of partnership strength into routine local preparedness measurement.
/ Administrative response capability. To improve measurement of administrative capabilities like hiring or procurement at STLT health departments, there may be an opportunity to build on existing data collection efforts. For example, NACCHO’s 2022 Preparedness Profile survey asked a sample of local health departments whether the following set of administrative capabilities were in place: (1) ability to receive and use emergency funding, (2) ability to reduce time to contract for or procure necessary goods and services, (3) ability to allocate or reallocate financial resources to pay for staff during an emergency, and (4) ability to reduce time required to hire staff or reassign existing staff.^166^ Between 23 and 37 percent of local health departments reported these capabilities were either not in place, or they were unsure if they were in place. The NACCHO tool is a valuable resource; further development of administrative capacity measures using NACCHO’s tool or something similar could enhance understanding of administrative capability trends across communities and over time.^VII^
/ Contextual factors affecting response and outcomes. Numerous social, political, economic, and environmental factors affect emergency response and outcomes but are outside the control of the public health and health care sector (Exhibit III.4). Incorporating measurement of these factors into public health preparedness indices would fail to consider the key measure attribute of “actionability.” Instead, routinely measuring and analyzing these contextual factors, and presenting them alongside preparedness measures within the control of the public health and health care sector, could help policymakers and the public understand areas for investment.^VIII^

Exhibit III.3 Survey instruments to measure the strength of partnerships among STLT public health departments and their partners

- The ADEPT index is intended for use by local health departments to assess engagement with cross-sector partners; however, it does not capture other partners’ perspectives on the relationships.^159^
- A survey tool to measure post-disaster resilience was developed and administered to 369 community-based organizations in New York, as well as the New York State Department of Health and Hygiene to measure partnership activity and resilience after Hurricane Sandy, but was not intended to assess preparedness broadly.^160^
- The Connectivity Measurement Tool includes a survey of multiple partners in public health emergency response about their perceived connectivity, but there is little research on the validity of the tool in peer-reviewed research.^161^

Exhibit III.4 Contextual factors affecting public health preparedness and response outcomes

- Social and health vulnerability^167^
- Political will^168^
- Public trust^169^
- Policies/laws/regulations ^170,171^
- Supply chain^172^
- Funding for public health^173^
- Built and natural environment context^174,175,176^

Exhibit III.5 Potential approaches to address strategy #1, and likely resource intensity of each

Examples of potential follow-up approaches | Likely resource intensity
- Advance individual training and measurement of training through professional associations. Conduct key informant interviews with key public health and health professional associations about interest in encouraging members to take a standardized emergency preparedness training and any outstanding needs or barriers to doing that; identify how progress could be made and measured (could lead to need for a Medium or High resource intensity follow-up to support the associations).; - Evaluate existing online preparedness curricula to begin setting a foundation for measurement of individual preparedness. Evaluate existing online curricula and obtain target audience input to suggest improvements to help optimize them.; - Explore degree program accreditation as a tool to improve readiness of future public health professionals and set a foundation for a national measure of individual preparedness. Meet with the Council on Education for Public Health, which accredits schools’ public health degree programs, to explore potential and any initiatives underway to increase “on-the-ground” training to 100 percent of students, and any initiatives promoting cross-training. | Low
- Develop new trainings to fill gaps to support improvement on future measurement of individual preparedness. Conduct a gap analysis and fill gaps in existing emergency preparedness curricula by developing new modules or trainings.; - Advance measurement of strength of essential partnerships. Review existing tools for measuring strength of partnerships as they relate to emergency preparedness, obtain input from the field, suggest possible adaptations needed for widespread use, and explore the feasibility of incorporating a survey-based measure into routine local preparedness measurement efforts.; - Investigate contextual factors critical to response and outcomes. Develop a method to quantify or assess contextual factors affecting emergency response and outcomes based on publicly available data sources; develop options for presenting these along with preparedness indices and gather target audience feedback on best way to consider these alongside preparedness. | Medium
- Improve measurement of administrative response capability and provide support to help STLT jurisdictions overcome barriers. Expand NACCHO or similar survey effort to capture administrative response capability across all local health departments, and survey them annually until they are all consistently reporting these capabilities. This effort should be paired with resources, including technical assistance, to overcome barriers to improving these capabilities.; - Develop a national-level measure or measures corresponding to administrative response capability. Track progress toward having 100 percent of new graduates in key fields enter the professional workforce with appropriate preparedness training. | High

Notes: Low-intensity=likely to require one to three staff working for less than a year; high-intensity=those that involve large-scale data collections or system changes; medium-intensity=efforts likely to fall between the low- and high-intensity ranges.

Low-intensity and italicized efforts could begin when resources are available. Italicized efforts are not dependent on low-intensity efforts to be completed first. Medium- and high-intensity efforts not italicized would best be structured using results from the low-intensity efforts listed.

### Strategy #2: Improve how health equity is addressed in preparedness metrics by engaging underserved communities in continuous efforts to advance measurement and considering social vulnerability data together with preparedness measures.

Incorporating health equity into preparedness measurement could be considered high priority and would strengthen the credibility and importance of existing metrics. The TEP emphasized the importance of health equity, citing literature on the disproportionate burden of COVID-19 disease and death on socially and medically vulnerable populations.^177^ In addition, addressing health equity in preparedness measurement aligns with new priorities identified by the COVID-19 Health Equity Task Force^IX^ and with CDC’s efforts to incorporate health equity into the Public Health Response Readiness Framework.^178^ PHEP requires its funding recipients to report on functional exercises involving critical workforce groups and disproportionately impacted populations. However, there are no current measures or indices that quantify preparedness to serve socially and medically vulnerable populations, such as those disproportionately impacted by COVID-19.

One way to approach the challenge of incorporating health equity into preparedness measurement is for researchers to engage frontline response staff at public health and health care organizations in identifying local needs for metrics and ways to capture the required data. Historically, measure development has relied on input from academic experts, as opposed to feedback from real-world, frontline response workers embedded in the communities where emergencies occur. Future measure development could prioritize community input and buy-in to ensure that measures are (1) feasible—that is, they will work given local circumstances; (2) credible, because they are informed by users themselves; and (3) important, because they are connected to desired outcomes based on end-user experiences.^X^ Local public health workers could be engaged along with first responders and emergency management personnel in developing hazard-specific metrics tailored to their communities, which were identified in the literature as missing from the "all-hazards approach” that most national frameworks and STLT tools take. Exhibit III.6 highlights an example of health equity in local preparedness metrics.

Explore optimal ways to communicate preparedness metrics alongside measures of social vulnerability to guide equitable allocation of resources. A community’s social and health vulnerability is highly correlated with emergency response and recovery outcomes regardless of the level of preparedness.^179^ Pairing social and health vulnerability information together with preparedness measures or indices could increase awareness of communities with low preparedness and particularly high vulnerability so policymakers could allocate resources effectively. This approach would require developing and testing a preferred format for communicating social vulnerability and preparedness measures together.

Examples of potential follow-up approaches are summarized in Exhibit III.7.

Exhibit III.6 Example of health equity in local hazard-specific preparedness metrics:

A jurisdiction may have a neighborhood with low average household income and a high percentage of people of color, and that neighborhood may also be physically low-lying or in a floodplain and as such, more at-risk for severe flooding. Because this neighborhood has specific needs that the rest of the jurisdiction does not, input from local responders, local public health workers, and community members could be convened to identify or create a preparedness metric to address their needs.

Exhibit III.7 Potential approaches to address strategy #2 and likely resource intensity of each

Examples of potential follow-up approaches | Likely resource intensity
- Develop recommendations for an effective approach to present social and health vulnerability indicators with or within preparedness indices. Mockup multiple options for displaying social and health vulnerability indicators together with preparedness indices and obtain feedback from target audiences to iterate to an effective approach or visualization method. Promote the visualization tool in conjunction with the release of indices. | Low
- Identify locally appropriate metrics focused on health equity to advance equity-focused preparedness measurement in communities. Select communities based on social vulnerability that are part of larger, less vulnerable cities or counties that are typically the unit for measurement. Engage front-line response staff to explore what metrics, including hazard-specific metrics, would capture emergency preparedness and how these metrics could be included for visibility as the larger area is assessed. | Medium to high, depending on number of communities included

Notes: Low-intensity=likely to require one to three staff working for less than a year; high-intensity=those that involve large-scale data collections or system changes; medium-intensity=efforts likely to fall between the low- and high-intensity ranges.

Low-intensity and italicized efforts could begin when resources are available. Italicized efforts are not dependent on low-intensity efforts being completed first. Medium- and high-intensity efforts not italicized would best be structured using results from the low-intensity efforts listed.

### Strategy #3: Improve source data and use additional analysis to enhance the availability, responsiveness, and salience of preparedness metrics.

Underused data sources—such as after-action reports and non-public data—as well as unconventional data sources, such as cell phone data, could help close gaps in data availability, particularly at the local level. Improving use of underused data is an appealing approach as it avoids burden from new data collection, but it presents other challenges that vary by data source. Below we highlight specific considerations for each potential data source; Exhibit III.10 provides a set of potential follow-up approaches to consider.

/ After-action reports (AARs). AARs are a promising data source for identifying factors that affect preparedness (Exhibit III.8)^181,182^ However, communities are not required to complete them after disasters, and there is no standardized format.^183,184^ While a standardized format would better facilitate cross-AAR analysis, an analysis identified strong AARs using varied methodologies and following different outlines,^185^ suggesting that imposing a single format may sacrifice utility for the localities that need the results. Another possibility is requiring a standardized metadata template, including categories summarizing frequent types of challenges and recommended improvements, as a way to facilitate cross-AAR analysis and learning without sacrificing flexibility.
  A concern raised by the TEP members is that AARs may be seen as perfunctory requirements and not as tools to inform future preparedness. One TEP member suggested future research could analyze AARs from different communities and disaster types, comparing findings to existing metrics and revising metrics to address challenges. Small-scale qualitative analysis of AARs has been conducted before^186^ and could be scaled up by using artificial intelligence to find patterns in reported processes and challenges. The availability of AARs would need to be explored; one data source could be the Homeland Security Digital Library, which houses an archive of AARs from jurisdictions across the United States, some of which are available publicly. The variable quality of the AARs will affect the usefulness of these data; improvements such as peer review of draft AARs could increase the value of AARs for both learning and improvement.^187^
/ Non-public data sources. Non-public data sources, such as health system data, could build an evidence base for the importance of measures. The environmental scan and TEP identified several non-public data sources that could help measure factors related to preparedness or link preparedness metrics to outcomes (Exhibit III.9). These data sources are restricted, so efforts to link measures and outcomes using this data would require data sharing agreements, de-identification, and other data security protocols.
/ Unconventional data collection and sources. The COVID-19 pandemic required creative approaches to obtaining urgently needed data. For example, surge periods during the pandemic required first responders to access hospital capacity data such as beds and key equipment available on a near real-time basis. To address this gap, the CDC’s National Healthcare Safety Network^XI^ (NHSN) provided a repository for hospitals (or state intermediaries) to frequently input important facility-level data. In addition, some states implemented their own statewide systems to share these data, such as New York’s publicly accessible Hospital Bed Capacity Dashboard.^XII^ Beyond facility-level preparedness data, a TEP member noted that many jurisdictions turned to nontraditional data such as cell phone data to track cases and social media data to track masking trends. Despite the critical information this type of infrastructure can convey, collecting these data can be burdensome and may be considered intrusive, so future efforts may need to explore making these data available solely during emergencies, rather than making them continuously available (as in the case of cell phone data).

Exhibit III.8 What is an after-action report?

As defined by FEMA, “An after-action report is developed after exercises and real-world incidents to summarize key information and continuous improvement-related analytical findings, including observations and recommended actions. It is a detailed and comprehensive document that describes what went well and what did not go well, considers why, and provides recommended actions.”^180^

Exhibit III.9 Examples of non-public data sources that could be leveraged to improve measurement of preparedness

- Non-public HPP data, such as data from the Real-World Incident Reporting and Evaluation Tool, and performance measure data.^188^
- Emergency management data maintained by vendors, cited by a TEP member as a central source of granular data from large numbers of hospitals on operations, capacity, and incidents.
- Data from large hospital systems; for example, a TEP member shared that one system’s readiness project includes 140 preparedness-related data points for more than 100 hospitals.

Exhibit III.10 Potential approaches to address strategy #3, and likely resource-intensity of each

Examples of potential follow-up approaches | Likely resource intensity
- Explore feasibility of use of AI with AARs. Test feasibility of using AI methods, including machine learning, to efficiently identify patterns in the challenges and learnings reported in AARs that could have implications for preparedness metrics.; - Explore stakeholder receptiveness to implementing a metadata template for AARs, and develop one if they are receptive, along with options for housing and accessing metadata. Could lead to a medium resource intensity project to build and encourage use of a new system.; - Explore feasibility and benefits of using non-public data sources such as those in Exhibit III.8 to advance the evidence base for preparedness metrics.; - Capture lessons learned from use of cell phone data and social media tracking during COVID-19. Explore how similar or improved use of these sources can be ready for future emergencies. | Low
- Analyze AARs on a large scale, to identify themes in response experience; reflect and report on the themes as they relate to current measurement and related needs; conduct follow up interviews to verify themes and identify any additional reflections.; - Facilitate improvement of AARs’ quality and availability, through peer review and support to ensure AARs are created and shared following all disasters.; - Undertake research using non-public data sources such as those in Exhibit III.8 to advance the evidence base for preparedness metrics, once feasibility and a strong plan have been established. | Medium
- Identify and develop automated data solutions that would reduce reporting burden, such as helping hospitals establish interfaces to automate NHSN submissions to obtain real-time, local data for key capacity measures. | High

Notes: Low-intensity=likely to require one to three staff working for less than a year; high-intensity=those that involve large-scale data collections or system changes; medium-intensity=efforts likely to fall between the low- and high-intensity ranges.

Low-intensity and italicized efforts could begin when resources are available. Italicized efforts are not dependent on low-intensity efforts to be completed first. Medium- and high-intensity efforts not italicized would best be structured using results from the low-intensity efforts listed.

### Strategy #4: Enhance actionability and understandability of metrics by developing and disseminating information on exemplars.

All-hazards preparedness indices may seem overwhelming to public health leaders given the extensive capabilities they measure, the distinct local contexts and risks to consider, and the complexity of cross-sector partnerships that are required. Presenting leaders with real-life examples of exemplary emergency response can highlight the feasibility of “getting it right.” For example, one TEP member noted, and another agreed, that it is important to showcase examples from hospitals or health systems that performed relatively well—across both health outcomes and financially—during the COVID-19 pandemic to encourage health systems to invest in preparedness. ASPR’s Healthcare Emergency Preparedness Information Gateway (known as ASPR TRACIE) provides examples of strong community-level responses, but more can be done to improve access to and use of exemplar cases. Exhibit III.11 presents examples of potential action items for consideration.

Exhibit III.11 Potential approaches to address strategy #4, and likely resource-intensity of each

Examples of potential follow-up approaches | Likely resource intensity
- Conduct a needs assessment to identify jurisdiction types, organizations, and disaster types most in need of exemplar models, and a landscape assessment to identify existing strong examples and find important gaps. Explore the key audience need through a small set of interviews to ensure subsequent case studies (a medium resource intensity approach) are designed to meet the needs. | Low
- Develop case studies to fill identified needs for exemplar models and disseminate them to relevant audiences. | Medium

Notes: Low-intensity=likely to require one to three staff working for less than a year; high-intensity=those that involve large-scale data collections or system changes; medium-intensity=efforts likely to fall between the low- and high-intensity ranges.

## C Discussion

The four strategies shared in this section offer potential directions for the future to address clear measurement gaps discussed in Chapter II. Ultimately, the availability of better tools to measure and understand gaps in preparedness against specific threats could inform federal and state resource allocation and help set priorities to improve preparedness of public health and healthcare system for the next public health threat. In the hands of dedicated leadership, better measurement can also catalyze and enable improvement, leading to a better-prepared nation.

Progress will depend on the interest and resources from government and nongovernment organizations leading the way in preparedness at all jurisdiction levels. Each involved organization—at the federal level to include ASPR, CDC, and FEMA—has its own preexisting priorities, and preparedness measurement improvement resources will inevitably compete with program support. The breadth of the suggested improvements should not discourage incremental enhancements. Incremental enhancements, such as any handful of the low- and medium-intensity efforts described above, especially if coordinated across organizations, could translate to a markedly better understanding of the status of preparedness among public health leaders, policymakers, and the general public, thanks to better measurement. The specific approaches that should be undertaken first depend, as a practical matter, on how managers within the relevant agencies find the efforts well-matched with existing work, resources, and program opportunities.

VII If a survey were expanded and implemented annually, there could be an opportunity to improve actionability: the same NACCHO survey identified barriers to administrative preparedness. Connecting health departments with resources to improve readiness based on barriers identified during the survey process would help make the measures actionable.

VIII A TEP member especially advocated for shining a light on government laws, policies, and regulations, providing an example of how a hiring freeze had prevented jurisdictions from hiring during COVID-19 despite the availability of federal funding to do so.

IX The Task Force was created through E.O. 13995 to make recommendations to the president for mitigating health inequities caused or exacerbated by the pandemic, and for preventing them in the future (Office of Minority Health. “COVID-19 Health Equity Task Force – Charter.” U.S. Department of Health and Human Services, January 2021. https://www.minorityhealth.hhs.gov/omh/browse.aspx?lvl=3&lvlid=118. OMH, 2022).

X The NHSPI included a stakeholder engagement and communications workgroup in 2017; however, the workgroup does not appear active today.

XI The CDC’s NHSN is the nation’s most widely used health care-associated infection tracking system, with most hospitals in the U.S. contributing data through a secure, web-based application, traditionally on a monthly or quarterly basis. https://www.cdc.gov/nhsn/index.html.

XII Bed occupancy data were required to input data on hospital and ICU beds available Monday through Friday on the State’s Electronic Response Data System; see https://coronavirus.health.ny.gov/hospital-bed-capacity.