# II The Current State of Public Health and Health Care Preparedness Metrics in the United States

The nation’s response to the COVID-19 pandemic provides an opportunity to better understand how to improve public health and medical response to all types of disasters, including infectious disease outbreaks, cybersecurity threats, and other emergencies. To seize this opportunity, we drew on findings from the environmental scan and TEP to address the following research questions, which are the basis of this chapter’s structure:

1. What metrics on public health and health care preparedness are currently available in the United States?
2. What are the gaps in existing public health and health care preparedness metrics?
3. What lessons learned from the COVID-19 pandemic can inform measurement of emergency preparedness and response at STLT public health agencies in the future?

Unless otherwise noted, this chapter focuses on tools that quantify preparedness in the United States across multiple phases of the emergency management cycle (that is, prevention, protection, mitigation, response, and recovery). We define preparedness tools as indices, measure sets, and other instruments (such as self-administered surveys) that are designed to quantify how prepared public health and health care systems are to respond to and recover from emergencies and disasters across multiple measures (Exhibit II.1). Exhibit II.2 and Appendix B summarize the existing STLT preparedness tools and serve as the foundation for the chapter. Given the study’s focus on preparedness metrics in the United States, Exhibit II.2 and Appendix B exclude: (1) global tools used to measure preparedness in other countries or to measure nation-level preparedness (for example, the Global Health Security Index); (2) tools that focus on a single phase or aspect of the emergency management cycle (for example, resilience or vulnerability indices); (3) tools that assess but do not quantify preparedness (for example, FEMA’s Community Threat and Hazard Identification and Risk Assessment, which describes a process communities can use to understand their risks and capabilities); and (4) tools that are not publicly accessible because they protected from disclosure under the Protected Critical Infrastructure Information Program (for example, Cybersecurity & Infrastructure Security Agency’s Infrastructure Survey Tool). ^III^

Exhibit II.1 Types of preparedness metrics

This chapter covers three types of metrics used to assess public health and health care emergency preparedness:

- Measures quantify specific aspects of emergency preparedness and response, such as whether a state has written disaster plans for long-term care and nursing facilities, or the percentage of adults receiving a seasonal flu vaccine.
- Indices create a composite statistic or score by collecting and aggregating data from multiple measures, helping audiences easily compare jurisdictions along various dimensions of emergency preparedness.
- Measure sets are lists of measures to help users quantify preparedness along various dimensions. Unlike indices, measure sets do not produce a composite score.

We use the term preparedness tools to describe indices and measure sets that assess preparedness across multiple measures.

## A What public health and health care preparedness tools are currently available in the United States?

In this section, we describe the tools that are currently available to assess STLT preparedness across multiple phases of the emergency management cycle. We focus on the following characteristics:

/ The number and types of tools
/ The tools’ purpose and intended users
/ The jurisdiction levels the tools apply to
/ How existing tools conceptualize preparedness
/ The types of disasters the tools address
/ Sources of data used to quantify preparedness in the tools

### 1 Number and types of available tools

There are relatively few tools designed to measure STLT public health and health care preparedness in the United States. The environmental scan found just nine preparedness tools for use at the STLT level in the United States, of which three have been used to assess national preparedness (Exhibit II.2; Appendix B). Of the nine tools, six were indices that produced composite scores and three were measure sets. In addition, there were three sets of capabilities maintained by federal agencies, which we describe below, but do not include in the list of tools because they do not quantify preparedness. The literature also described a variety of tools to measure country-level preparedness; prominent examples are in Exhibit II.3.

Exhibit II.2 List and description of tools to assess STLT public health and healthcare preparedness

Tool | Description
Tools for internal and external stakeholders
Community Outbreak Preparedness Index (COPI) ^20^ | Assesses county-level preparedness for infectious disease outbreaks using publicly available data
Hospital Medical Surge Preparedness Index^21^ | Evaluates the capacity of hospitals to handle patient surges during mass casualty events, using over 120 measures from publicly available data sources
Hospital Preparedness Program (HPP) performance measure set^22^ | Assesses preparedness of HPP funding recipients based on 22 performance measures reported by recipients and disseminated broadly
National Health Security Preparedness Index (NHSPI) ^23^ | Generates a composite preparedness score for states, territories, and the nation overall based on 130 measures derived from publicly available data sources
Trust for America’s Health (TFAH) Ready or Not tool^24^ | Evaluates states’ preparedness for public health emergencies using a targeted set of 10 measures largely derived from the NHSPI
Self-administered tools for internal use by STLT jurisdictions
Assessment for Disaster Engagement with Partners Tool (ADEPT) ^25^ | Summarizes the frequency and nature of activities related to disaster preparedness, response, and recovery that local health departments engage in with community-based organizations, using a 15-item index for use by local health departments
Connectivity Measurement Tool^26^ | Quantifies the level of connectivity of different organizations and systems involved in public health preparedness across 28 items
Preparedness Capacity Assessment Survey (PCAS) ^27^ | Creates an aggregate score summarizing preparedness of local health departments
Rapid Urban Health Security Assessment (RUHSA) ^28^ | Evaluates local-level health security capacities across 46 measures

The most prominent STLT preparedness tool we found in the literature is the NHSPI. First released in 2013 and updated annually using publicly available data, the NHSPI assesses U.S., state, and territorial health preparedness for a wide range of emergencies and disasters. Scores are disseminated publicly to inform planning efforts by internal and external stakeholders. In the literature, four peer-reviewed articles focused on the NHSPI, and nearly all articles that described U.S. preparedness tools mentioned the NHSPI as relevant background.^36,37,38,39^ The NHSPI was developed with input and support from a variety of funders and partners, initially including the CDC and the Association of State and Territorial Health Officials, and beginning in 2016, the Robert Wood Johnson Foundation. The most recent edition of the NHSPI uses more than 60 publicly available data sources across 130 measures to create an overall preparedness score for each U.S. state on a scale of 1 to 10.^40^ The tool also produces a score for each state across six domains: health security and surveillance; community planning and engagement; incident and information management; health care delivery; countermeasures management; and environmental and occupational health.

Existing tools contain a varying number of measures. Several of these tools are designed to measure preparedness broadly across 50 or more measures (such as the NHSPI, COPI, the HMSPI, RUHSA). Others have a narrower focus and fewer measures, such as the ADEPT, which contains 15 items focused specifically on local health departments’ partnerships to prepare for, respond to, and recover from disasters, or the TFAH tool, which assesses preparedness across a focused set of 10 measures that are largely derived from the NHSPI.

Exhibit II.3 Prominent global tools to measure national public health and health care preparedness

Although this report focuses on U.S. tools to measure STLT preparedness, there are a variety of tools used globally to measure country-level preparedness. Prominent global preparedness tools include:

- Oppenheim et al.’s Epidemic Preparedness Index. Assesses national-level preparedness for infectious disease outbreaks.^29^
- Global Health Security Index. Assesses and benchmarks health security and related capabilities. This tool was originally developed in partnership among Nuclear Threat Initiative, Johns Hopkins Center for Health Security, and Economist Impact, with Brown University Pandemic Center supporting development of the most recent edition.^30^
- Pan American Health Organization’s Preparedness Index for Emergencies and Disasters. Estimates the capacity of national health care systems to deal with and recover from emergencies and disasters.^31^
- World Health Organization’s Joint External Evaluation Tool. Measures capacity and progress toward nine technical areas to assess a nation’s capacity to prevent, detect, and rapidly respond to public health threats.^32^

As detailed in Appendix C, the COVID-19 pandemic exposed limitations in the predictive validity of many of these global tools.^33^, ^34^, ^35^

In addition to the tools highlighted in Exhibit II.2, FEMA, CDC, and ASPR maintain lists of capabilities that are also intended to guide STLT public health preparedness. Although not intended to quantify and summarize preparedness like indices or measure sets, FEMA, CDC, and ASPR each maintain sets of capabilities and associated resources and trainings to guide STLT jurisdictions’ efforts to prepare for and respond to emergencies. For example, FEMA maintains a list of 32 core capabilities that communities need to advance emergency preparedness.^41^ CDC and ASPR maintain similar sets of capabilities and guidance for STLT public health agencies and health care coalitions,^IV^ respectively.^42,43^ Although these three sets of capabilities are intended for different users, contain different numbers of capabilities, and use different organizing domains to group the capabilities, all three are designed to be flexible and adaptable to meet the needs of all STLT jurisdictions, which vary in size, geography, and governance structures.^44,45,46^ However, these capabilities sets are largely intended for self-administration and do not produce composite scores or other data sets that allow for quantitative comparison across jurisdictions. Exhibit II.4 highlights similarities and differences across these three capability sets.

Exhibit II.4 Characteristics of sets of capabilities from FEMA, CDC, and ASPR

Characteristic | FEMA’s National Preparedness Goal Core Capabilities^41^ | CDC’s Public Health Emergency Preparedness and Response Capabilities^42^ | ASPR’s Health Care Preparedness and Response Capabilities^43^
Intended user or target audience | Whole communities | STLT jurisdictions and their public health agencies | Multisector health care coalitions, including health care organizations and public health agencies
Purpose | To assist everyone who has a role in preventing, protecting against, mitigating, responding to, and recovering from the threats and hazards that pose the greatest risk | To serve as national standards for STLT public health | Lists the necessary attributes for the health care system to save lives and continue to function in advance of, during, and after a response
Initial release year | 2011 | 2011 | 2012
Most recent release year | 2015 | 2018^a^ | 2017
Number of capabilities | 32 | 15^a^ | 4^b^
Domains | - Prevention; - Protection; - Mitigation; - Response; - Recovery | - Community resilience; - Incident management; - Information management; - Countermeasures and mitigation; - Surge management; - Biosurveillance | - Foundation for health care and medical readiness; - Health care and medical response coordination; - Continuity of health care service delivery; - Medical surge

a CDC launched the Next Generation of the Public Health Emergency Preparedness Program (PHEP) initiative in 2020, which may impact capability standards.

b ASPR expects to release an updated set of capabilities in 2024 that will add four new capabilities to the set (for a total of eight).

The COVID-19 pandemic exposed that preparedness tools—such as the NHSPI, TFAH tool, and other prominent global tools—were not accurate predictors of COVID-19 outcomes.^47,48,49,50^ For example, the NHSPI did not successfully predict excess mortality rates at the outset of the COVID-19 pandemic even though the tool was assessed for construct validity during its development and continues to undergo validity and sensitivity testing on an ongoing basis as new sources of public health emergency data emerge. ^51,52,53^ Appendix C summarizes literature on preparedness tools’ accuracy in predicting COVID-19 outcomes. Even before the COVID-19 pandemic, the evidence-base for preparedness tools was limited because the relative rarity of public health emergencies limited the use of real-world data to validate tools.^54^

### 2 Purpose and intended users

Five tools summarize preparedness for broad audiences, including internal and external stakeholders. The NHSPI, HMSPI, COPI, and TFAH tools all use publicly available data to generate results that are disseminated broadly and can be easily interpreted by a wide range of internal and external users. These users may include federal, state, and local officials; public health and health practitioners and administrators; multisector coalitions; researchers; communications specialists; and the general public.^55,56,57^. In addition, data from the HPP measure set are available for use by internal and external users. Although the HPP measure set is designed to be completed by HPP funding recipients and to inform federal program monitoring, data from the HPP measure set are publicly available in easy-to-use visualizations that show and compare how states and health care coalitions performed.^58^

Four tools are self-administered; they have a narrower focus and more targeted audience. The ADEPT, Connectivity Measurement Tool, PCAS, and RUHSA are self-guided tools that local jurisdictional leaders can use to assess preparedness and identify areas for improvement.^59,60,61^ For example, the ADEPT tool collects data from local health department staff and their partners to measure the strength of local health departments’ partnerships with community-based organizations to prepare for, respond to, and recover from emergencies.^62^ Unlike the tools described above, results from the self-administered tools are intended for internal stakeholders only, and are not routinely shared with a broad audience.

### 3 Jurisdiction levels

Two tools measure state and territorial preparedness, although additional tools produce results that can be aggregated at the state level. The NHSPI is a comprehensive tool to measure and summarize preparedness at the state and territorial levels. ^63^, Similarly, the TFAH tool, which consist of nine measures from the NHSPI and an additional measure of state public health spending trends, provides another way for states to compare themselves to others and assess areas for improvement.^64^ Further, some of the other tools that collect data within states, such as the HPP performance measure set, can be rolled up to the state level to understand preparedness across the state.

Seven tools assess preparedness at a local level—such as at the county, local health department, or hospital level—but they have noteworthy limitations that could be addressed through additional research and new or innovative sources of local data. For example, the COPI creates a composite outbreak preparedness score at the county level and assesses a wide range of measures across the emergency management cycle, but is a relatively new tool and consequently, has not been widely used or validated across settings.^65^ Similarly, the HMSPI assesses preparedness at the hospital level, but the index has not been widely validated against hospital performance during actual disasters.^66^. The HPP measure set includes measures of preparedness for health care coalitions, but the size and composition of health care coalitions varies across localities, making the data difficult to compare. A few tools, such as the ADEPT, Connectivity Measurement Tool, PCAS, and RUHSA, measure the emergency preparedness of local health departments, but are self-assessment tools intended to be completed by staff at the public health departments and are not publicly reported (which would allow for comparison across local health departments). New or untapped sources of local data could support development of new tools that could facilitate comparison of local jurisdictions’ preparedness and inform federal and STLT planning efforts.

Three of the STLT tools can assess preparedness at the national level. Results from two tools—the NHSPI and HPP measure set—are routinely aggregated at the national level to present a snapshot of national preparedness (an example from NHSPI is shown in Exhibit II.5). In addition, the TFAH tool groups states into tiers based on scores for each measure, which can be used to assess national preparedness, for example by assessing the number or percentage of states in the highest performing tier for each measure to assess relative strengths and weaknesses across the United States.

Exhibit II.5 Example of national preparedness data available on the NHSPI website

Note: The dashboard is available on the NHSPI website (https://nhspi.Org/#by-state) and includes preparedness scores for the nation and by state, including the overall preparedness level and preparedness scores by domain.

This exhibit is a screen shot of the national preparedness snapshot available on the NHSPI website. It shows that the U.S. had a national preparedness level of 6.8 out of 10, with domain-level scores ranging from 5.0 to 8.9 across the six domains.

### 4 How existing tools conceptualize preparedness

A few tools take a comprehensive approach to defining and measuring preparedness and include measures that address all five phases of emergency management. Comprehensive indices like the NHSPI and COPI include measures aligned with all five phases of the emergency management cycle (prevention, protection, mitigation, response, and recovery).^67,68^ Tools with fewer measures and a narrower focus, such as the ADEPT or the HPP measure set, tend to focus on measuring jurisdictions’ efforts to develop and implement emergency response plans related to prevention, mitigation, and response. Exhibit II.6 highlights examples of measures from select tools across the five phases of emergency management.

STLT preparedness tools include a mix of proactive and reactive measures. Proactive measures for disaster preparedness identify potential risks and establish best practices to mitigate their impact— aligning with the prevention, protection, and mitigation phases of emergency management—whereas reactive measures focus on post-event response and recovery.^69^ The tools we found generally contain a mix of both types of measures. Examples of common proactive measures of preparedness include accreditation of public health and health care facilities, measures quantifying the size of vulnerable populations, such as children, adults ages 65 and older, or people eligible for Medicaid, and measures of social capital, such as housing affordability or voter turnout. The tools also contained numerous reactive measures focused on the ability to respond to threats, such as the number of burn care beds or emergency response teams, access to volunteers (measured as the number of registered Medical Reserve Corp volunteers or the number of partnerships with volunteer entities), and availability of personal protective equipment, among others.

Exhibit II.6 Examples of measures that assess various aspects of the five phases of emergency management from select preparedness tools, including the NHSPI, COPI, HPP measure set, and ADEPT

Emergency management phase^a^ | Examples of measures from select tools
Prevention. Ability to avoid, prevent, or stop imminent threats | - Number of epidemiologists per 100,000 population in the state, by quintile (NHSPI); - Population coverage for wastewater surveillance testing (COPI); - Percentage of health care coalitions engaged in their recipient’s (state or large local health department’s) jurisdiction risk assessment (HPP measure set); - State health department participates in a broad prevention collaborative addressing health care–associated infections (NHSPI)
Protection. Ability to secure the homeland against acts of terrorism and disasters | - Percentage of bridges that are in good or fair condition (transportation structural integrity) (NHSPI); - Number of infrastructure companies (e.g., utility and communications companies) and local public safety agencies (e.g., law enforcement) participating in the health care coalition (HPP measure set)
Mitigation. Ability to reduce loss of life and property by lessening the impact of disasters | - Number of obstetricians and gynecologists per 100,000 female population in the state (NHSPI); - Pediatric vaccination rate (defined as proportion of county’s children with all required immunizations for school enrollment) (COPI); - Whether programs have conducted community outreach side-by-side with community-based organization staff to reach vulnerable and hard-to-reach populations (ADEPT); - Percentage of HCCs that access the de-identified emPOWER data map at least once every six months to identify the number of individuals with electricity-dependent medical and assistive equipment for planning purposes (HPP Measure Set)
Response. Ability to save lives, protect property and the environment, and meet basic humans needs after an incident | - State public health laboratory has a plan for a six-to-eight-week surge in testing capacity to respond to an outbreak or other public health event, with enough staffing capacity to work five 12-hour days for six to eight weeks in response to an infectious disease outbreak (NHSPI); - Number of community emergency response team (CERT) programs in a county per capita (COPI); - Program has coordinated the use of a community-based organization facility during a disaster (ADEPT); - Percentage of HCCs that have a complete and approved response plan annex addressing the specialty surge requirement (HPP measure set)
Recovery. Ability to help communities recover effectively | - Percentage of employed population in the state engaging in some work from home by telecommuting (NHPSI); - Quality of unemployment (UE) benefits (defined as ratio of state maximum weekly UE benefits divided by county’s average supplemental poverty measure threshold) (COPI)

a Emergency management phases and definitions are from the FEMA National Preparedness Goal.^44^

ADEPT = Assessment for Disaster Engagement with Partners Tool; COPI = Community Outbreak Preparedness Index; HCC = health care coalition; NHSPI = National Health Security Preparedness Index; HPP = Hospital Preparedness Program.

Numerous tools measure specific aspects of preparedness, such as vulnerability or resiliency. Social vulnerability and community resilience play an important role in preparedness and are pertinent to health outcomes after emergencies and disasters.^78^ To strengthen individual and community resilience in the U.S., HHS recently developed the Federal Plan for Equitable Long-Term Recovery and Resilience, which lays out an approach for federal agencies to cooperatively strengthen the vital conditions for health and well-being.^79^ Although it is widely accepted that social vulnerability and resilience affect preparedness, there are competing views on the extent that these measures and other contextual factors should be included in preparedness tools. Some researchers believe these factors affect preparedness and so should be incorporated in indices,^80^ but others suggest that preparedness indices should only measure factors within the immediate control of jurisdictions.^81^ These tensions contribute to overarching challenges defining and conceptualizing preparedness. Although we do not focus on these tools in this chapter, Exhibit II.7 highlights several examples of tools that measure resilience and vulnerability.

Exhibit II.7 Examples of tools to measure health and social vulnerability or resilience^78^

- Baseline Resilience Indicators for Communities^70^
- Community Disaster Resilience Index^71^
- Community Resilience Estimates^72^
- Community Resilience Index^73^
- COVID-19 Community Vulnerability Index^74^
- COVID-19 Vulnerability Index^75^
- COVID-19 Pandemic Vulnerability Index^76^
- Social Vulnerability Index (SVI)^77^

### 5 Types of disasters addressed

Many tools take an “all-hazards” approach that measures preparedness for a range of disasters rather than for a specific type of disaster or emergency.^82^ Eight of the nine tools take an all-hazards approach to measuring preparedness across emergency situations, including natural disasters; communicable disease outbreaks; cyberattacks; acts of terrorism; and risks related to chemical, biological, radiological, nuclear, and explosive incidents. Consequently, most measures within these tools are relevant to a range of disasters—for example, NHSPI’s “percentage of local health departments in the state with an emergency preparedness coordinator” or TFAH’s “change in state public health spending” measure— rather than targeting skills and resources needed by emergency type, such as whether a state has an evacuation route in place if a hurricane occurs.

The COPI is the only one of the nine tools we reviewed that focuses on preparedness for infectious disease outbreaks.^V^ Before the COVID-19 pandemic, there were a few global tools—like the Epidemic Preparedness Index, Global Health Security Index, and Infectious Disease Vulnerability Index^87^— that assessed countries’ preparedness to respond to infectious disease emergencies. A March 2023 study cited the need for additional measures to quantify preparedness and response capabilities for pandemics and infectious disease outbreaks specifically in the United States.^88^ In response to the lack of local-level tools and COVID-19, a team at a California-based nonprofit developed the COPI to assess county-level preparedness across the five phases of emergency management for an outbreak of an infectious disease. The index measures strengths and gaps in areas such hospital surge capacity, nursing home staffing, insurance coverage and access to primary care, using over 30 data sources. It includes new data sources developed in response to COVID-19, such as the Centers for Medicare and Medicaid Services’ Nursing Home COVID-19 Vaccination Data.

There are some efforts to measure components of STLT preparedness for natural disasters. Exhibit II.8 highlights examples of disaster-specific tools related to wildfire smoke exposure, hurricanes, tsunamis, and extreme heat. Although many of the factors assessed in these tools overlap with the all-hazards tools described above—such as measures of community socioeconomic status and unemployment— they also include factors that are specific to types of disasters. For example, the TsunamiReady guidelines include a measure of whether the community has produced tsunami evacuation maps, and the ReadyMapper data visualization tool, which has been used during wildfires and hurricanes, includes variables of population-level movement to show where people are evacuating from and where they are going.^89^

Exhibit II.8 Examples of tools that measure components of STLT preparedness for specific disasters

Examples of tools that measure components of STLT preparedness for specific disasters include:

- Community Health Vulnerability Index. Measures county-level vulnerability to wildfire smoke exposure. Health officials can use the tool in combination with air quality models to focus public health strategies on areas where air quality is impaired.^83^
- ReadyMapper. Tracks and measures response— including population mobility, infrastructure damage, and health system response capacity— during natural disasters. ReadyMapper was used during the wildfires in California and in the Hurricane Ida response in Louisiana.^84^
- National Weather Service’s TsunamiReady program and associated guidelines. Establishes 16 guidelines for communities to work towards to mitigate, prepare for, and respond to tsunamis.^85^
- Heat Vulnerability Index. Assesses factors associated with adverse health effects during extreme heat to identify communities at the greatest risk and inform mitigation efforts, such as setting up cooling centers in vulnerable areas where many people do not have access to air conditioning.^86^

### 6 Data sources

Four tools leverage data from public sources, including national surveys, government agencies, and associations. The NHSPI, COPI, HMSPI, and TFAH tool all rely on publicly available data to inform measurement (Exhibit II.9). The NHSPI uses publicly available data from 64 sources to calculate states’ preparedness scores,^90^ and the COPI uses data from more than 30 sources.^91^ A limitation to using publicly available data is that there are often lags in availability. For example, the latest NHSPI report, released in 2021, relies on data from 2020 and earlier, and the COPI report released in 2023 draws on some data sources dating back to 2014.

Five preparedness tools rely on self-reported data. The ADEPT, Connectivity Measurement Tool, PCAS, and RUHSA are self-assessment tools, meaning the data are collected and used by the jurisdiction only.^92,93,94,95,96,97^ Although this approach expands the types of measures that can be assessed because tool developers are not limited by data availability, self-assessment tools do not allow for comparison across jurisdictions. Similarly, self-reported data are prone to response bias.^98^ The HPP measure set is also self-reported by HPP funding recipients but results are disseminated publicly for external stakeholders.

Exhibit II.9 Examples of data sources used to measure preparedness in existing tools, by level (state and/or local) that the data are available

| State | Local
Survey data
American Hospital Association Annual Survey | ✓ | ✓
Association of Public Health Laboratories All-Hazards Laboratory Preparedness Survey | ✓
Association of Public Health Laboratories Comprehensive Laboratory Services | ✓
Association of State and Territorial Health Officials Profile Survey | ✓
Centers for Disease Control and Prevention’s Behavioral Risk Factor Surveillance System | ✓ | ✓
Centers for Disease Control and Prevention’s Youth Risk Behavior Survey | ✓ | ✓
Robert Wood Johnson Foundation’s National Longitudinal Survey of Public Health Systems^a^ | ✓ | ✓
National Association of City and County Health Officials Profile of Local Health Departments | | ✓
U.S. Census Bureau’s American Community Survey | ✓ | ✓
U.S. Census Bureau’s Current Population Survey | ✓
Publicly available data from government agencies
Agency for Healthcare Research and Quality Pediatric Quality Indicators | ✓ | ✓
Agency for Toxic Substance and Disease Registry Environmental Justice Index | ✓ | ✓
Administration for Strategic Preparedness and Response Hospital Preparedness Program measure data | ✓ | ✓
Administration for Strategic Preparedness and Response Medical Reserve Corp data | ✓
Bureau of Labor Statistics Occupational Employment Statistics | ✓ | ✓
Centers for Disease Control and Prevention’s National Snapshot of Public Health Preparedness | ✓
Centers for Disease Control and Prevention’s National Health care Safety Network Prevention Status Reports | ✓
Centers for Disease Control and Prevention’s Funding Recipient lists | ✓
CDC’s National Vital Statistics System data | ✓
Centers for Medicare & Medicaid Services Hospital Compare | ✓ | ✓
Centers for Medicare & Medicaid Skilled Nursing Facility Quality Reporting Program data | ✓ | ✓
Federal Emergency Management Association Community Rating System | ✓ | ✓
Health Resources and Services Administration data on health care shortage areas | ✓ | ✓
National Plan & Provider Enumeration System National Provider Identifier registry | ✓ | ✓
Data from associations and other organizations
Association of Public Health Laboratories member list | ✓ | ✓
Leapfrog group hospital safety score | ✓ | ✓
NACCHO Project Public Health Ready participation | | ✓
National Emergency Management Association data | ✓
Penn State University Social Capital Index composite score of civic engagement | | ✓
Public Health Accreditation Board member list | ✓ | ✓
United States Election Project General Election Turnout Rates | ✓

Note: Mathematica compiled the data sources in this table by reviewing the source lists for the NHSPI and HMSPI. The list focuses on publicly available data sources and is not meant to be exhaustive. We define local level data as any data available within states (such as data from a county, hospital system, health care coalition, or hospital). Survey data available at the local level may only be available for a sample of local jurisdictions.

a The survey was originally funded by the Centers for Disease Control and Prevention before the Robert Wood Johnson Foundation became the primary funder.

## B What are the gaps in existing public health and health care preparedness metrics?

In this section, we describe gaps in preparedness metrics, including gaps in:

/ Factors that are measured in existing indices and measure sets
/ Jurisdiction levels for which the preparedness tools are designed
/ Types of disasters addressed
/ Available data
/ Other areas (including limitations)

### 1 Gaps in factors that are measured

Existing preparedness tools do not fully capture several important predictors of preparedness and response capacity. Next, we describe the predictors of preparedness that the literature and TEP cited as missing or insufficiently captured in preparedness measurement; they are also summarized in Exhibit II.10.

Exhibit II.10 Spotlight on the technical expert panel: Factors that are inadequately captured in existing metrics

Technical expert panel (TEP) members highlighted several important factors that affect preparedness in the U.S., but are inadequately captured in existing preparedness indices and tools:

- Partnerships and cross-sector collaboration (mentioned 11 times by TEP members)
- Individual training and preparedness (mentioned 11 times by TEP members)
- Administrative capacity to hire and scale up operations (mentioned seven times by TEP members)
- Political factors (mentioned six times by TEP members)
- Social vulnerability (mentioned six times by TEP members)
- Public trust (mentioned five times by TEP members)

Source: Mathematica’s analysis of TEP data.

Current preparedness tools do not adequately assess partnerships and cross-sector collaboration. It is well documented that cross-sector collaboration between public health, health systems, community-based organizations, laboratories, and other organizations is critical for promoting resource sharing and engaging communities and volunteers in preparedness, response, and recovery.^99,100,101,102^ However, both the literature and the TEP emphasized the need for better measures of cross-sector collaboration; in fact, this was one of the most prominent TEP themes. ^103^ A TEP member noted that it can be resource intensive to collect the survey data needed to assess relational coordination.

We can see these weaknesses when we examine specific tools. For example, the NHSPI has a sub-domain dedicated to “cross-sector/community collaboration” that includes six measures, but these measures (which rely on publicly available data) do not capture the extent to which a state and its localities have plans and systems in place to collaborate during emergencies.^VI^ Likewise, a known weakness of the HMSPI is that it includes publicly available measures of individual hospitals’ preparedness for mass casualty events, but it does not measure the synergies between hospitals that would improve collective response.^104^ On the other hand, the HPP performance measure set is specifically designed to collect and summarize information about cross-sector health care coalitions and the extent to which their member organizations partner with each other.^105^ However, HPP funding recipients cite challenges with burdensome reporting requirements.^106^

“Being able to measure relational coordination and connectivity is something we did learn from the COVID-19 pandemic. That is a measure that is really important [for preparedness].”

— TEP member

Existing metrics fail to consider whether the individuals working in public health and health organizations are adequately trained to perform their duties. TEP members highlighted that numerous tools measure the number and types of staff in an organization, but do not assess how they have been trained and whether that training gives them the ability to effectively respond to an emergency. TEP members pointed out that ill-prepared leadership across sectors and a lack of real-world experience among epidemiologists and other experts are both key limitations of existing metrics. The CDC’s guidance document summarizing public health capabilities includes detailed suggestions on individual skills and training needs to meet the required capabilities,^107^ which implies that STLT public health agencies may have this information to guide their planning, but it is not currently assessed in indices and measure sets.

TEP members highlighted the need for additional measures to assess STLT health departments’ administrative capacity to hire staff and scale up operations during emergencies. TEP members noted that a variety of metrics are designed to measure epidemiological or public health laboratory capacity (for example, number of epidemiologists per 100,000), but fewer measures examine functions like human resources and procurement (for example, staff who support recruitment, training, payroll and benefit administration, and purchasing). The COVID-19 pandemic exposed how critical such measures are, as many STLT public health departments struggled to quickly hire staff and source computers and other basic supplies for contact tracing operations and COVID-19 testing sites.^108^

‘What we’re finding now is that [key questions are,] “Can you move people, money, stuff, and data around quickly? Do you have the systems and authorities in place to allow you to do that? Can you hire quickly? Can you buy things quickly?”’

— TEP member

Preparedness indices do not capture the importance of political factors in public health preparedness and response outcomes. Existing tools do not measure the presence of effective political leadership^109,110^ or how political leanings might affect public health operations and outcomes.^111^ Several TEP members expanded on this, noting that measuring the presence of a public health emergency response plan, as many existing indices do, is not sufficient when political leaders have the power to prevent these plans from being executed.

“You can have capacity, you can have the capability, and people could be robustly prepared … but if the political will isn’t there, [it’s not] going to happen.”

— TEP member

Existing metrics do not adequately measure STLT jurisdictions’ preparedness to mitigate, respond to, and recover from emergencies affecting socially and medically vulnerable populations. Most of the comprehensive preparedness indices that we focused on for this report attempt to assess risks for some vulnerable populations, but also exclude important subgroups. For example, the NHSPI has a sub-domain on “at-risk populations.” The four measures in the domain focus on children and people who are pregnant, but do not measure other important groups that may be at elevated risk of experiencing adverse effects from disasters, such as people living with disabilities or people who are uninsured. On the other hand, indices focused exclusively on vulnerability (such as those in Exhibit II.7) may help to identify communities that may need support before, during, or after disasters based on socioeconomic factors, household characteristics, racial and ethnic composition, and housing types and transportation, but they miss other critical factors related to preparedness, such as emergency planning and surge capacity. Several TEP members reinforced this finding, emphasizing the importance of identifying communities that are most vulnerable to disasters and the extent that these communities are receiving the support they need to prevent, mitigate, respond to, and recover from emergencies. The literature highlighted opportunities to combine social vulnerability data from tools like CDC’s Social Vulnerability Index with results from preparedness tools to improve the predictive capability of existing preparedness tools for underserved communities.^112,113^

TEP members highlighted a need for measures of public trust in government. Public trust in the government had important implications for population-level health behaviors and outcomes during the COVID-19 pandemic.^114^ TEP members noted that this factor is not adequately addressed in existing preparedness measures and should be explored. A starting point could be examining existing metrics that quantify public trust in government (Exhibit II.11).

### 2 Gaps by jurisdiction type

Currently, there is no comprehensive all-hazards index to measure and guide local jurisdictions’ emergency preparedness efforts. Although there are a handful of tools to measure preparedness across localities within states (for example, at the county or local health department level), none of these tools comprehensively quantify local public health preparedness across disaster types. Existing tools at the local level either have a somewhat narrow focus, such as the ADEPT tool’s focus on partnerships for preparedness and response, or HMSPI’s focus on hospital surge plans and capacity, or are intended for self-administration rather than broader dissemination, such as the PCAS and RUHSA. Further, although the recently developed COPI takes a comprehensive approach to assessing preparedness for infectious disease outbreak at the county level, its focus on infectious disease and lack of widespread validation may limit its usefulness on a broad scale.

This is a critical gap that makes it challenging for federal and state officials to understand which communities and local public health departments are less prepared and need additional resources and support to address emergencies. The TEP mentioned this gap, noting that the lack of a local all-hazards index makes it challenging for similarly sized communities to compare themselves to each other and prioritize areas for improvement. However, there are trade-offs to consider. One TEP member cautioned that all-hazards indices at the local level may be challenging for localities to use and interpret, given the notable variation in size, geographic characteristics, and governance structure across local jurisdictions. This TEP member suggested that hazard-specific tools may be easier for local jurisdictions to use. Another TEP member cautioned that STLT jurisdictions may fear political consequences and the stigma of “being at the bottom of the list” if they have a low preparedness score. Because local organizations such as public health agencies, hospitals, and other health care and social service providers are on the front lines of emergency responses, it is important to consider options for developing additional tools to understand community-level preparedness.^119^

Exhibit II.11 Examples of metrics that quantify public trust in government

Several indices quantify public trust in government across multiple dimensions. For example:

- The Citizen Trust in Government Organizations scale includes nine items measuring citizens’ perception of government agencies’ competence, benevolence, and integrity.^115^
- The Trust in Government Measure quantifies public trust as it relates to population health interventions and public health messaging. The tool includes 17 items related to perceptions of the government’s capability, effectiveness, judgement, beneficence, and integrity.^116^

In addition, a few U.S. organizations collect and track standalone measures of citizens’ self-reported trust in government. For example:

- Pew Research Center estimates the percentage of people in the U.S. who trust the government to do what is right "just about always", "most of the time", "only some of the time" or "never" based on polling data.^117^,
- A survey conducted by the Harvard T. H. Chan School of Public Health asks respondents to rate their level of trust in federal, state, and local public health agencies using a four-point Likert scale. ^118^

Tribal communities need tailored metrics to help them assess preparedness and response. FEMA’s pre-disaster recovery guide for tribal governments highlights the need for special considerations for tribal communities when planning for emergencies.^120^ For example, the guide encourages tribal communities to consider the presence of sacred or historic land when taking inventory of assets during emergency preparedness exercises, and emphasizes the criticality of cross-jurisdictional coordination (including intergovernmental agreements with state, local, and other tribal governments) given the sovereignty of federally recognized tribes. Yet the existing preparedness tools and the related literature do not discuss implications or use of measurement tools with or by tribal organizations, suggesting that potential gaps may exist in measuring preparedness within tribal nations and communities. More recently, FEMA released the 2022–2026 National Tribal Strategy, which expands on the FEMA national preparedness goal by addressing its responsibilities to tribal nations.^121^ One aim of the National Tribal Strategy is to develop tribal-specific technical assistance resources and case studies to help Tribal Nations reach goals related to preparedness, protection, mitigation, response, and recovery. Although metrics could help set and track progress toward these goals, it will be critical that any tools to assess the preparedness of tribal groups are developed in close consultation with tribes and do not have any unexpected consequences.

### 3 Gaps by disaster type

Most preparedness tools discussed here were designed to assess “all hazards” preparedness, which may not reliably predict outcomes for all types of emergencies. The literature and TEP members highlighted that all-hazards indices do not reliably predict outcomes for all types of emergencies and may be challenging for jurisdictional users to use to improve preparedness.^122^ This was evidenced during the COVID-19 pandemic, when numerous studies found that all-hazards indices were poor predictors of COVID-19 mortality rates. (See Appendix C.)^123,124,125^ TEP members highlighted unique challenges in measuring preparedness for infectious disease outbreaks—borne out by the experience of the COVID-19 pandemic—such as the need to plan for a sustained response over many months or years, reduction in routine program functions, changing priorities and policies, and the critical role of public health leaders relative to other common types of responders, such as fire and rescue. These challenges also apply to measuring preparedness for other emergency situations, such as concurrent disasters (e.g., a hurricane occurring during an infectious disease outbreak) or cascading hazards (e.g., a tsunami triggering electrical grid failure that ultimately results in a nuclear power plant incident).

There are potential gaps in preparedness metrics for emergent threats, such as cybersecurity threats, natural disasters, and other hazards. Infectious disease outbreaks are not the only type of hazard that require specialized plans. Cybersecurity threats require extensive planning that may not be captured in all-hazards indices. For example, the NHSPI assesses the existence of data systems to coordinate emergency response, but does not measure plans if these data systems are breached or inoperable due to cybersecurity attacks.^127^ A 2023 report released by the White House highlighted the need for a national cybersecurity strategy, including approaches to measure preparedness for cybersecurity threats.^128^ Similarly, natural disasters have unique preparedness needs. For example, planning for storms and floods involves determining evacuation routes, planning to protect food and water from contamination, and developing communication plans to update the public during power outages.^129^ With the growing threat of cyber-related service disruptions and natural disasters and rising concerns about the hazards listed in Exhibit II.12, it is important to ensure there are ways to adequately measure STLT preparedness for these types of events.^130,131^

Exhibit II.12 Local health departments' perception of preparedness by threat

The 2022 NACCHO Survey of Local Health Department Preparedness asks respondents to assess their own preparedness and concern for 23 different threats/hazards.^126^ Among the 23 hazards, there are seven hazards on which their concern was substantially higher than they thought their preparedness was (defined as a difference of 20 percentage points [ppts] or more):

- Opioid abuse and overdose (58 ppt difference)
- Medical supply chain disruptions (38 ppt difference)
- Cyber-related threats (35 ppt difference)
- Active shooter (24 ppt difference)
- Critical infrastructure protection (24 ppt difference)
- Storms/ flooding (23 ppt difference)
- Vaccine-preventable diseases (23 ppt difference)

### 4 Gaps in available data

There are gaps in data sources used to measure preparedness at the local level. Many data sources are only available for public use at the state or national level (Exhibit II.9), and only about half of these data sources are available at the sub-state level. The literature attributes the lack of comprehensive indices at the local level, in part, to the lack of standardized data collection among local public health agencies,^132,133^ as well as challenges related to interoperability (for example, incompatible software and systems, diverse data sources, STLT-level regulations around data sharing, and concerns about data security and privacy) and the lack of a public health IT infrastructure network.^134^

Data are not always timely. Several TEP members mentioned that static measures of preparedness can be misleading because they only capture a single point in time and are not regularly updated. This is especially true of assessing measures of response capacity such as vacant hospital beds or availability of personal protective equipment. Many data sources like national surveys tend to be collected sporadically and may have lags between the times when data are collected and when they are publicly available. There is a growing need to identify data sources that are frequently updated and rapidly available for public use so more timely measures of preparedness are available.

“Static measures [of preparedness] give us a lot of misleading information about what capacity we do or do not have.”

— TEP member

### 5 Other gaps and limitations

The scan highlighted a few additional limitations in STLT jurisdictions’ ability to use existing preparedness tools, such as challenges adapting scores from indices to their local contexts and using the tools for goal setting. This suggests that there is a need for greater STLT engagement in developing and refining metrics, and in informing development of technical assistance tools to support use and interpretation of metrics. A few TEP members said it can be difficult for STLT jurisdictions to interpret and adapt preparedness scores from existing indices to their unique context to identify the greatest threats and risks their own community faces. Furthermore, for both state and local jurisdictions, preparedness tools lack benchmarks to help guide goal setting and improvement. Although indices like the NHSPI contain helpful information to summarize preparedness, the literature cites challenges at the STLT level in using this information to set goals and guide improvement.^135^ Moving forward, those responsible for developing and improving metrics should consider ways to continuously engage STLT jurisdictions and their partners in developing, testing, and refining tools. This would increase awareness of tools and ensure they are actionable for end users.^136,137,138^

## C What lessons learned from the COVID-19 pandemic can inform measurement of emergency preparedness and response at STLT public health agencies in the future?

Experiences from the COVID-19 pandemic offer critical takeaways that can inform the development of more robust and effective measures in the future. Below, we highlight some of these lessons learned.

The COVID-19 pandemic exposed preparedness tools’ lack of predictive validity. As noted in section II.1 and described in detail in Appendix C, numerous studies found that preparedness tools—including the NHSPI, TFAH tool, and prominent all-hazards global tools—were poor predictors of COVID-19 mortality rates.^139,140,141^ This underscores the need to explore ways to improve measurement within existing tools and consider whether all-hazards tools are the best way to assess preparedness for the wide range of unique emergencies that the country is likely to face. It also highlights the need to test and refine existing tools on an ongoing basis as new sources of public health emergency data become available.

During the pandemic, researchers uncovered a variety of factors associated with public health outcomes that should be considered and measured when assessing emergency preparedness. As highlighted in Section II.B, factors such as strength of partnerships, political will, public trust, and social vulnerability were shown to be associated with key outcomes during the pandemic, and TEP members underscored them as noteworthy gaps in existing metrics. We can improve our understanding of preparedness by finding ways to measure these factors. Relatedly, a few TEP members noted that there is potential to use artificial intelligence to expedite review of after-action reports and qualitative data on preparedness to discover additional factors to measure.

The COVID-19 pandemic underscored the need to embed equity into emergency preparedness and response systems, and thus, into how we measure communities’ preparedness and assess their vulnerabilities. It is well documented that the COVID-19 pandemic disproportionately impacted historically marginalized communities.^142,143^ For example, one study showed that communities with higher rates of social and health vulnerability had significantly lower health security levels as measured by the NHSPI.^144^ This underscores the need for emergency preparedness systems to adopt approaches that promote equitable crisis response processes and outcomes. Examples of equitable approaches to crisis response include creating diverse crisis response teams and partnering with community organizations known to local communities, who can help build trust and support communication with groups at elevated risk of poor health outcomes due to structural and systemic barriers. The CDC recently implemented the Public Health Response Readiness Framework, which includes health equity as one 10 program priorities. The 2024–2028 PHEP notice of funding opportunity (NOFO) embeds health equity requirements in the NOFO’s three overarching strategies.^145^However, there remains a need to develop equity-focused preparedness metrics that align with the changes to the CDC framework and incorporate them in existing indices and tools to quantify inequities in preparedness. This need is further articulated in a 2023 report from the American Medical Association, which calls for improved collection of demographic and social needs data (such as race and ethnicity, language, disability status, and gender identity) to reliably detect, measure, and evaluate inequities in crisis preparedness and response.^146^

Investments in data infrastructure could improve measurement of preparedness, especially at the local level where measurement is limited by a lack of standardized data sources. The COVID-19 pandemic exposed many weaknesses in the public health data and surveillance infrastructure in the United States, including limitations in reporting and tracking lab test results, lack of interoperability across health care and public health reporting systems, and gaps in the types of data that are collected and tracked, among others.^147,148^ Improved data infrastructure, sharing, and collection was mentioned nearly 20 times by members of the expert panel. This is especially true at the local level, where lack of timely, standardized data (along with other factors such as limited resources, local priorities, and so on) makes it challenging to create composite measures of preparedness. CDC’s multibillion dollar Data Modernization Initiative, which began in 2020, aims to improve data infrastructure to make it easier for STLT public health agencies to report data (including data related to preparedness) and for state and federal officials to use these data to inform decision making. TEP members noted that better data infrastructure—including systems that are updated with data in real time—could help the nation transition from point-in-time measurement of preparedness to continuous assessment, which would be a significant advance. To support data infrastructure improvements, many TEP members highlighted that federal and STLT public health agencies need additional funding and other resources so they can invest in new data systems and support ongoing changes to the ones they have.

Although existing metrics have been updated and improved substantially in the last decade, the evidence base for public health and health care preparedness metrics remains weak, and substantial work remains at all levels—national, state, local, tribal territorial, and the private sector—to ensure the United States is prepared to respond to federal public health and health care emergencies.^149^ Although the development of tools like the NHSPI, TFAH tool, COPI, and others listed in Appendix B has advanced STLT preparedness measurement, noteworthy gaps remain in public health preparedness metrics and in STLT emergency preparedness more broadly. For example, a 2023 Government Accountability Office (GAO) report stated that substantial deficits in the federal government’s preparedness for emergencies remain—noting that GAO had made 155 recommendations to HHS for improvements in the prior ten years, and only 64 had been implemented. In the wake of the COVID-19 pandemic, the literature also highlights the need for improvements to other aspects of the U.S. public health infrastructure—such as building the public health workforce, advancing the collection and use of public health data, and enhancing communication from public health agencies to the communities they serve—to enhance preparedness for future emergencies.^150^ Improving tools to measure public health preparedness is key to tracking the nation’s progress towards emergency preparedness goals, but the lack of consensus on how preparedness should be conceptualized and defined in preparedness frameworks, capabilities lists, and tools complicates the path to success in this area. Looking forward, it will be important to know which strategies can address the gaps in preparedness metrics so the federal government and STLT public health agencies can find the weaknesses and better allocate resources to improve emergency preparedness nationwide.

III Although we excluded these tools from the main analysis of themes and gaps presented in Chapter II, we reviewed and cite literature related to these tools as it relates to overarching themes and gaps in preparedness metrics.

IV Health care coalitions are defined as multisector groups of health care and response organizations—including public health agencies—within a geographic area.^46^

V As noted in Exhibit II.6, several tools specifically assess state and local vulnerability and resilience to COVID-19—and not other infectious diseases—but do not focus on preparedness.

VI Examples of measures in this NHSPI domain include “state health department accredited by the Public Health Accreditation Board” and “percent of hospitals in the state that participate in health care preparedness coalitions through the Hospital Preparedness Program.” See NHSPI 2020 Measure Set.