# I Introduction

A wide range of recent domestic disasters have highlighted the challenge of preparing for large-scale public health emergencies. Since 2020, the U.S. Department of Health and Human Services (HHS) has issued 57 declarations of new and continuing public health emergencies for a range of crises, including infectious diseases such as COVID-19 and monkeypox; natural disasters such as wildfires, hurricanes, and severe storms; and the ongoing opioid epidemic.^2,II^ Inadequate preparation for these disasters has resulted in preventable loss of life; diminished public trust in federal, state, tribal, local, and territorial (STLT) governments; and ongoing confusion about the actions needed to improve public health and health care preparedness (Exhibit I.1).

Exhibit I.1 What is public health and health care preparedness?

Public health and health care preparedness is the ability of public health and health systems, communities, and individuals to prevent, protect against, mitigate, quickly respond to, and recover from health emergencies. ^1^

Three federal agencies provide critical guidance and funding to help STLT jurisdictions and public health and health care systems nationwide advance emergency preparedness. The U.S. Centers for Disease Control and Prevention (CDC) and the Administration for Strategic Preparedness and Response (ASPR) maintain sets of core capabilities that public health and health care systems need to achieve preparedness. In addition, the Federal Emergency Management Agency (FEMA) maintains a set of 32 capabilities intended to guide emergency preparedness broadly at the community level, helping to achieve FEMA's National Preparedness Goal, organized across five mission areas (Exhibit I.2).^4^ Collectively, since 2002, federal agencies, including CDC, ASPR, and FEMA, have distributed more than $75 billion in funding to help STLT jurisdictions and public health system partners prevent, prepare for, and respond to emergencies.^5,6,7^

Exhibit I.2 FEMA's National Preparedness Goal and the five phases of emergency preparedness

FEMA defines the National Preparedness Goal as “a secure and resilient Nation with the capabilities required across the whole community to prevent, protect against, mitigate, respond to, and recover from the threats and hazards that pose the greatest risk.” FEMA further describes five categories, or “mission areas,” needed to support this goal:^3^

1. Prevention. Ability to avoid, prevent, or stop imminent threats Example capability: Intelligence and information sharing
2. Protection. Ability to secure the homeland against acts of terrorism or disasters Example capability: Supply chain integrity and security
3. Mitigation. Ability to reduce loss of life and property by lessening the impact of disasters Example capability: Community resilience
4. Response. Ability to save lives, protect property and the environment, and meet basic human needs after an incident Example capability: Public health, health care, and emergency medical services
5. Recovery. Ability to help communities recover quickly Example capability: Housing

Because communities face distinct hazards, public health and health care emergency preparedness strategies vary from jurisdiction to jurisdiction. For example, a rural community in a low-lying coastal region would necessarily prioritize different preparedness capabilities than a landlocked city prone to tornadoes. While guidance from the CDC, ASPR, and FEMA is designed to support emergency preparedness across a broad range of disaster types (Exhibit 1.3), these agencies also encourage routine hazard or risk assessments to help communities understand distinct threats they face and prioritize capabilities based on local needs. FEMA requires government agencies to work with stakeholders to conduct a thorough community risk assessment every three years using the Community Threat and Hazard Identification Risk Assessment to guide their work.^9^ Similarly, CDC's Public Health Emergency Preparedness (PHEP) program requires funded public health agencies to work with local jurisdictions and their community partners to conduct a risk assessment at least once every five years.^10^ Risk assessments are also common at the facility (such as hospital or nursing home) level. For example, health care facilities that participate in Medicare or Medicaid are required to complete or update a hazard vulnerability analysis annually to better understand risks and prioritize activities to mitigate, respond to, and recover from these risks.^11^

Exhibit I.3 An all-hazards approach to preparedness

The capabilities advanced by CDC, ASPR, and FEMA are designed to be adaptable across all hazard types: natural disasters; infectious disease outbreaks; terrorist attacks; cybersecurity attacks; and chemical, biological, radiological, or nuclear incidents. This all-hazards approach to preparedness recognizes that “while hazards vary in source (natural, technological, societal), they often challenge health systems in similar ways and demand a multisectoral response.”^8^

Preparing for emergencies requires planning and collaboration across a multitude of public and private sector partners that play distinct roles in public health and health care emergency response. For example, CDC’s public health preparedness and response capability standards include STLT public health departments, health clinics, ambulatory care providers, fire departments, law enforcement agencies, public works, and other partners as contributors to medical surge capabilities; first responders, epidemiologists, environmental health agencies, clinical laboratories, and other partners as contributors to laboratory testing capabilities; and social service agencies, schools, community coalitions, mental health providers, housing programs, and other partners as contributors to community recovery capabilities.^12^ Similarly, ASPR’s Health Care Preparedness and Response Capabilities are designed for multisector health care coalitions (HCCs) consisting of public health agencies, hospitals, emergency medical services, and emergency management organizations located in a defined geographic location.^13^

The landscape of organizations that make up the public health system and contribute to public health and health care preparedness is varied and complex. Exhibit I.4 presents the broad network of partners involved in emergency preparedness and response. Partners range from health clinics and emergency medical services (EMS) that provide direct health care services, to employers and schools that play key roles in ensuring safe workplaces and learning environments, such as encouraging testing and vaccination, as many employers and organizations did during the COVID-19 pandemic.

Exhibit I.4 Entities that might make up a local public health emergency preparedness system

Image adapted from NACCHO (https://www.naccho.org/uploads/downloadable-resources/Programs/Public-Health-Infrastructure/FINAL-Local-Instrument.pdf), “Local Assessment Instrument.” National Association of City and County Health Officials, 2013.

This exhibit shows the range of entities that are involved in preparing for and responding to public health emergencies, including public health agencies, tribal health organizations, elected officials, laboratories, hospitals, schools, community health clinics, employers, fire departments, home health, nonprofit organizations, civic groups, and many other types of entities.

Assessing whether a jurisdiction is prepared for different emergencies is inherently complex, and there is a lack of consensus among practitioners and scholars on how to measure preparedness. Despite the promise and potential of preparedness measurement (Exhibit 1.5), tools introduced in recent decades have numerous limitations: inconsistently defining preparedness and its goals, relying on subjective agency assessments of the standards and capabilities that contribute to preparedness, and failing to provide an evidence base for measures.^15,16,17^ The cross-sectoral, cross-jurisdictional nature of public health systems adds to the complexity of preparedness measurement; because of the many agencies and organizations involved in emergency response, it is challenging to understand how performance should be measured and accountability distributed across these partners.^18^ The singularity of public health emergencies is a central challenge. Because each disaster is unique, it is difficult to assess whether key takeaways from one disaster will apply to the next.^19^

Exhibit I.5 Why measure preparedness?

Measuring preparedness can provide a powerful decision-making tool to guide strategies to ensure a community of any size is ready for an emergency. Stoto and Nelson^14^ present three core aims of preparedness measurement:

1. Accountability. Measures can help hold leaders and public health system partners accountable for their investments in preparedness by allowing them to assess preparedness relative to set standards or benchmarks.
2. Systems improvement. Measures can highlight where weaknesses and gaps exist across the public health system, driving quality improvement efforts.
3. Research and knowledge sharing. Over time, as measures are tested and refined, they can help build evidence on “what works” when preparing for emergencies, which is key to informing the study of public health preparedness.

The COVID-19 pandemic exposed flaws in U.S. emergency response systems, demonstrating the urgent need for more reliable, evidence-based preparedness measures. Public health and health care systems faced extraordinary pressures, from staffing a qualified workforce to meeting surging demand for medical care to addressing the stark health inequities that persisted across communities. Given the significance of the pandemic and its lasting impact, a close examination of current approaches to preparedness measurement, including key drivers of preparedness that may have been overlooked, is essential to inform readiness for infectious disease outbreaks and other potential disasters.

In response to the issues outlined above, HHS’s Office of the Assistant Secretary for Planning and Evaluation (ASPE) funded this study, designed to draw lessons from the COVID-19 pandemic to inform efforts to measure preparedness going forward. The study included a targeted environmental scan of domestic preparedness metrics and a technical expert panel (TEP)—made up of representatives from federal agencies, public health and health care organizations, and academic institutions—with diverse experience in preparedness measurement and emergency response.

This report gives a comprehensive overview of the current landscape of preparedness measurement tools and suggests areas for improvement, exploring why current efforts to measure preparedness have failed to predict effective responses in real-world settings. In addition, to inform future measurement efforts, it reveals key criteria that preparedness metrics should meet and highlights strategies that could potentially advance measurement to meet these criteria and address the gaps found in current metrics of public health and health care preparedness.

The research questions in Exhibit I.6 guided this work. Questions 1–3 focus on current measures and are addressed in Chapter II; Questions 4 and 5 look to the future of public health preparedness measurement and are addressed in Chapter III. In addition, Appendix A describes the study methods, Appendix B describes existing tools to measure STLT emergency preparedness, Appendix C summarizes literature assessing how well preparedness indices predicted outcomes during the COVID-19 pandemic, Appendix D lists the TEP participants, and Appendix E provides the agenda for the TEP.

Exhibit I.6 Study research questions

1. What public health and health care preparedness tools are currently available in the United States? (Chapter II)
2. What are the gaps in existing public health and health care preparedness metrics? (Chapter II)
3. What lessons learned from the COVID-19 pandemic can inform measurement of emergency preparedness and response at STLT public health agencies in the future? (Chapter II)
4. What attributes should public health and health care preparedness metrics have, and what gaps would these attributes address? (Chapter III)
5. What strategies should potentially be explored to improve measurement of public health and health care preparedness? (Chapter III)

II This count includes both new public health emergency declarations and declarations that have been renewed by the Secretary of the Department of Health and Human Services for ongoing emergencies, such as the opioid crisis and COVID-19.