# Appendix E Technical Expert Panel Agenda

A. Welcome and Stage Setting
B. Breakout Session 1: Current Measures
  1. What is your experience with currently available measures and their strengths and weaknesses?
  2. What did COVID-19 teach us about measures?
  3. What important aspects of the literature on public health and health-care preparedness measures were not addressed in the environmental scan?
C. Breakout Session 2: Future Measures
  1. What impact should measures have?
  2. How should public health and health-care preparedness be measured?
  3. What are common data sources that could be used for future measures?
D. Group Discussion: Framework Development
  1. What current and future measures can inform the development of a framework?
  2. Should the COVID-19 experience drive the development of public health and health-care preparedness measures?
  3. Should the framework be based on threats, hazards, capabilities, or capacities?
E. Summary Remarks and Conclusion